# APPENDIX D DEFINITIONS OF GENERAL AND SPECIFIC DIETARY SOURCES OF TOTAL WATER AND TAPWATER

Dietary Sources
Specific | General^1^ | | USDA Description of Food Group or Food Item(s)^2^
1. Drinking Water | D | --
2. Baby Formula | B | 117 | Baby Formulas
3. Milk | B | 111 | Milk, Fluid-Pasteurized, Filled, Buttermilk, Dry Reconstituted
| B | 112 | Milk, Concentrated Fluid (Canned)
| B | 113 | Milk, Imitation
4. Milk Drinks | B | 115 | Chocolate, Malted, Shakes, Other Flavored Milk Drinks
| B | 116 | Meal Replacements with Milk
5. Other Dairy | F | 114 | Yogurt
| F | 118 | Milk, Dry and Powdered Mixtures with Dry Milk, Not Reconstituted
| F | 121 | Sweet Dairy Cream (Fluid Whipped or Dry)
| F | 122 | Sweet Cream and Whipped Cream Substitutes
| F | 123 | Sour Dairy Cream
| F | 131 | Milk Desserts, Frozen
| F | 132 | Milk Desserts, Not Frozen
| F | 134 | Milk Sauces and Gravies
| F | 135 | Other Milk Products
| F | 141 | Natural Cheese
| F | 142 | Cottage Cheese
| F | 143 | Cream Cheese
| F | 144 | Processed Cheeses and Cheese Spreads
| F | 145 | Imitation Cheese
| F | 146 | Cheese Mixtures
| F | 147 | Cheese Soups
6. Meat, Poultry, Fish, and Mixtures | F | 210 | Meat, nfs, and Beef, nfs
6. Meat, Poultry, Fish, and Mixtures | | 211 | Beef Steak with Bone
| F | 212 | Beef Steak without Bone
| F | 213 | Beef Cuts with Bone, Not Steaks
| F | 214 | Beef Slices or Chunks
| F | 215 | Ground Beef Patties, Meat Balls
| F | 216 | Other Beef Items
| F | 220 | Pork, nfs
| F | 221 | Pork Chops
| F | 222 | Pork Steak or Cutlet
| F | 223 | Ham
| F | 224 | Pork Roasts, not Ham
| F | 225 | Canadian Bacon
| F | 226 | Bacon and Salt Pork, Fat Back
| F | 227 | Misc. Pork Cuts
| F | 230 | Lamb, nfs
| F | 231 | Lamb
| F | 232 | Veal
| F | 233 | Game
| F | 241 | Chicken
| F | 242 | Turkey
| F | 243 | Duck
| F | 244 | Rock Cornish Game Hen and Other Poultry
| F | 251 | Organ Meats and Mixtures
| F | 252 | Frankfurters, Sausages, Lunchmeats, Meat Spreads
| F | 261 | Finfish
| F | 262 | Other Seafood
| F | 263 | Shellfish
| F | 271 | Meat, Poultry or Fish in Gravy, Sauce, or Creamed
| F | 272 | Meat, Poultry or Fish Combined with Starch Items
| F | 273 | Meat, Poultry or Fish with Starch and Vegetable
| F | 274 | Meat, Poultry or Fish with Vegetable, Excluding White Potatoes
| F | 275 | Sandwiches (Reported as a Unit) with Meat, Poultry or Fish
| F | 281 | Frozen Plate Meals
| F | 283 | Soups, Broths, Extracts, from Meat, Poultry or Fish Base
| B | 284 | Gelatin Drink, Plain
| F | 285 | Gravies, Meat or Poultry Base Made with Water
7. Eggs and Egg Dishes | F | 311 | Chicken Eggs
7. Eggs and Egg Dishes | F | 312 | Other Poultry Eggs
| F | 321 | Egg Dishes
| F | 322 | Egg Sandwiches
| F | 323 | Egg Soups
| F | 324 | Meringues
| F | 330 | Egg Substitutes, nfs
| F | 331 | Egg Substitutes, Made from Powdered Mixtures
| F | 332 | Egg Substitutes, Made from Frozen Mixtures
| F | 333 | Egg Substitutes, Made from Liquid Mixtures
8. Legumes, Nuts, and Seeds | F | 411 | Cooked or Canned Dried Beans
| F | 412 | Cooked or Canned Dried Bean, Mixtures
| F | 413 | Cooked Dried Peas, and Lentils Mixtures
| F | 414 | Soybean Dried Products
| F | 415 | Frozen Meals with Dried Beans or Peas as Main Course
| F | 416 | Soups, Mainly Legumes
| F | 418 | Meat Substitutes
| F | 419 | Meat Substitute Sandwiches
| F | 421 | Nuts
| F | 422 | Nut Butters
| F | 423 | Nut Butter Sandwiches
| F | 424 | Coconut Beverages and Mixtures
| F | 425 | Nut Mixtures
| F | 431 | Seeds
| F | 441 | Carob Powders
| F | 442 | Carob Chips
9. Grain Products | F | 500 | Flour and Dry Mixes
| F | 510 | Breads, Rolls, nfs
| F | 511 | White Bread, Rolls
| F | 512 | Whole Wheat Bread, Rolls
| F | 513 | Cracked Wheat Bread, Rolls
| F | 514 | Rye Bread, Rolls
| F | 515 | Oatmeal Bread
| F | 516 | Multigrain Bread
| F | 517 | Cottonseed Bread
| F | 518 | Other Breads
| F | 521 | Biscuits
| F | 522 | Cornbread and Corn Muffins
| F | 523 | Other Muffins, Popovers
| F | 524 | Quickbreads Excluding Cornbread and Muffins
| F | 531 | Cakes
| F | 532 | Cookies
| F | 533 | Pies
| F | 534 | Cobblers, Eclairs, Turnovers, Other Pastries
| F | 535 | Danish, Breakfast Pastries, Bars, and Doughnuts
| F | 536 | Coffee Cake, not Yeast Type
| F | 541 | Sweet Crackers
| F | 542 | Low Sodium (Dietary Crackers)
| F | 543 | Nonsweet Crackers
| F | 544 | Salty Snack Products from Grain Sources
| F | 551 | Pancakes
| F | 552 | Waffles
| F | 553 | French Toast
| F | 554 | Crepes
| F | 555 | Flour Water Patties
| F | 556 | Flour Milk Patties
| F | 557 | Rice Flour Cakes
| F | 561 | Pastes
| F | 562 | Cooked Cereals
| F | 571 | Cereal, Ready-to-Eat, nfs
| F | 571 | Buckwheat Cereal
| F | 572 | Bran Cereals
| F | 573 | Corn Cereals
| F | 574 | Oat Cereals
| F | 575 | Rice Cereals
| F | 576 | Wheat Cereals
| F | 577 | Multigrain Cereals
| F | 579 | Other Cereals
| F | 581 | Mixtures with Animal Protein
| F | 582 | Mixtures without Animal Protein
| F | 583 | Frozen Plate Meals
| F | 584 | Soups with Grain Product as Main Ingredient
10. Citrus Juice | B | 612 | Citrus Fruit Juices
11. Noncitrus Fruit Juice and Tomato Juice | B | 641 | Juices (Exclude Citrus)
11. Noncitrus Fruit Juice and Tomato Juice | B | 642 | Nectars
| B | 743 | Tomato Juice
12. Fruit | F | 611 | Citrus Fruits
| F | 621 | Dried Fruits
| F | 631 | Fruit, Exclude Berries
| F | 632 | Berries
| F | 633 | Mixtures of 2 or More Fruits
| F | 634 | Mixtures of Fruits, Berries, and Nonfruit Items
13. Potatoes | F | 710 | White Potatoes, nfs
| F | 711 | Baked, Boiled, Canned
| F | 712 | Chips, Sticks
| F | 713 | Creamed, Scalloped, Au Gratin
| F | 714 | Fried
| F | 715 | Mashed, Stuffed, Puffs
| F | 716 | Salad
| F | 717 | Special Recipes
| F | 718 | Soups
| F | 719 | Puerto Rican Starchy Vegetables
| F | 771 | White Potato Mixtures
| F | 772 | Puerto Rican Starchy Vegetables (Viandas) Mixtures
| F | 775 | Puerto Rican Stews or Soups with Starchy Vegetables (Viandas)
14. Vegetables and Tomatoes | F | 721 | Dark-Green, Leafy Vegetables
| F | 722 | Dark-Green, Not Leafy Vegetables
| F | 723 | Dark-Green Vegetable Soups
| F | 731 | Carrots
| F | 732 | Pumpkin
| F | 733 | Squash
| F | 734 | Sweet Potatoes
| F | 735 | Deep-Yellow Vegetable Soups
| F | 741 | Raw Tomatoes
| F | 742 | Cooked Tomatoes
| F | 744 | Tomato Sauces
| F | 745 | Tomato Mixtures
| F | 746 | Tomato Soups
| F | 747 | Tomato Sandwiches
| F^3^ | 751 | Raw Vegetables
| F^3^ | 752 | Cooked or Canned Vegetables with or without Added Fat
| F | 753 | Cooked Vegetables, Mixture of 2 or More Vegetables (Include Nuts) with or without Added Fat
| F | 754 | Cooked Vegetables with Sauces, Batters, Casseroles
| F | 755 | Olives, Pickles, Relishes (Exclude Tomatoes)
| F | 756 | Vegetable Soups
| F | 773 | Other Vegetable Mixtures (with Animal Protein)
15. Fats, Oils, Dressings, and Soy Sauce | F | 811 | Table Fats
15. Fats, Oils, Dressings, and Soy Sauce | F | 812 | Cooking Fats
| F | 813 | Other Fats
| F | 821 | Vegetable Oils
| F | 831 | Regular Type Salad Dressings
| F | 832 | Low-Calorie Type Salad Dressings
| F | 0020020 | Soy Sauce
16. Sugars and Sweets | F | 911 | Sugars
| F | 912 | Sugar Replacements or Substitutes
| F | 913 | Syrups, Honey, Molasses
| F | 914 | Jellies, Jams, Preserves
| F | 915 | Gelatin Desserts, Salads
| F | 916 | Ices, Popsicles
| F | 917 | Candies
| F | 918 | Chewing Gum and Cough Drops
17. Tea | B | 923 | Tea
18. Coffee | B^4^ | 921 | Coffee
19. Coffee Substitutes | B^4^ | 922 | Coffee Substitutes
20. Soft Drinks, Regular (Carbonated) | B | 924–0000 | Soft Drink, nfs
20. Soft Drinks, Regular (Carbonated) | B | 924–1011 | Carbonated Water, Sweetened (Quinine Soda) (Include Tonic, Fizzie Tablet)
| B | 924–1031 | Cola Type
| B | 924–1041 | Cream Soda
| B | 924–1051 | Fruit Flavored Sodas (Citrus, Cherry, Grape, Strawberry, Tom Collins Mixer, Whiskey Sour Mix, Apple Beer)
| B | 924–1061 | Ginger Ale
| B | 924–1071 | Root Beer
| B | 924–1081 | Chocolate Flavored Soda
| B | 924–1151 | Cola with Fruit or Vanilla Flavor
| B | 924–1152 | Cola with Chocolate Flavor
| B | 924–1401 | Soft Drink, Carbonated, Malt (Include Malta India, Martita)
| B | 924–1601 | Mavi Drink
21. Softdrinks, Lo-Cal or No-Cal, Carbonated | B | 924–1021 | Carbonated Water, Unsweetened (Club Soda)
21. Softdrinks, Lo-Cal or No-Cal, Carbonated | B | 924–2000 | Special Dietary Drinks, Carbonated, with Artificial Sweetener (Include Diet Colas, Root Beer)
22. Fruit Drinks, Regular, and Other Soft Beverages | B | 924–3100 | Soft Drinks, Noncarbonated, Made From Powdered Mix, with Sugar, Fruit Flavor
| B | 924–3051 | Soft Drinks, Noncarbonated, Made From Powdered Mix, with Sugar, Vitamin C Added, Fruit Flavored Fruitades and Drinks
| B | 925–0010 | Drink nfs
| B | 925–1011 | Apple Drink
| B | 925–1012 | Apple-Cherry Drink (Include Apple-Grape, Apple-Raspberry, Apple-Pineapple)
| B | 925–1021 | Apricot-Orange Drink
| B | 925–1022 | Apricot-Pineapple Drink
| B | 925–1030 | Banana Drink
| B | 925–1031 | Banana-Orange Drink
| B | 925–1041 | Black Cherry Drink
| B | 925–1042 | Black Cherry-Orange Drink
| B | 925–1051 | Cranberry Drinks
| B | 925–1061 | Fruit Drinks
| B | 925–1065 | Puerto Rican Tamarind Drink (Refresco de Tamarindo)
| B | 925–1071 | Fruit Punch
| B | 925–1072 | Fruit Punch (Fruit Juice and Ginger Ale)
| B | 925–1073 | Fruit Punch (Soda, Fruit Juice, Sherbert, or Ice Cream)
| B | 925–1075 | Genipop (Jagua) Drink
| B | 925–1081 | Grapeade
| B | 925–1082 | Grape Drink (Include Grape Ice)
| B | 925–1083 | Grape-Lemon Drink
| B | 925–1091 | Grapefruit Drink
| B | 925–1095 | Guava Drink
| B | 925–1101 | Lemonade (Include Frozen Lemonade Reconstituted)
| B | 925–1102 | Lemon-Limeade
| B | 925–1111 | Limeade
| B | 925–1121 | Orangeade
| B | 925–1122 | Orange Drink
| B | 925–1123 | Orange-Apricot Drink
| B | 925–1124 | Orange-Lemon Drink
| B | 925–1130 | Pineapple Drink
| B | 925–1131 | Pineapple-Grapefruit Drink
| B | 925–1132 | Pineapple-Lemon Drink
| B | 925–1133 | Pineapple-Lime Drink
| B | 925–1134 | Pineapple-Orange Drink
| B | 925–1151 | Strawberry Drink
| B | 925–3011 | Apple Drink with Vitamin C Added
| B | 925–3021 | Black Cherry Flavored Drink with Vitamin C Added
| B | 925–3031 | Cherry Drink with Vitamin C Added
| B | 925–3032 | Cherry Flavored Drink with Vitamin C Added
| B | 925–3041 | Citrus Drink with Vitamin C Added
| B | 925–3051 | Cranberry Juice Cocktail with Vitamin C Added
| B | 925–3052 | Cranberry-Apple Drink with Vitamin C Added
| B | 925–3061 | Fruit Punch with Vitamin C Added
| B | 925–3071 | Grape Drink with Vitamin C Added
| B | 925–3081 | Grapefruit Drink with Vitamin C Added
| B | 925–3091 | Lemonade with Vitamin C Added
| B | 925–3101 | Orange Drink with Vitamin C Added
| B | 925–3102 | Orange Flavored Drink with Vitamin C Added
| B | 925–3111 | Pineapple-Grapefruit Drink with Vitamin C Added
| B | 925–3112 | Pineapple-Orange Juice Drink with Vitamin C Added
| B | 925–3121 | Strawberry Drink with Vitamin C Added
| B | 925–4101 | Grape Drink Made From Powdered Mix with Sugar and Vitamin C Added
| B | 925–4102 | Lemonade Made From Powdered Mix with Sugar and Vitamin C Added
| B | 925–4103 | Orangeade Made From Powdered Mix with Sugar and Vitamin C Added
| B | 925–4200 | Fruit Flavored Drinks with High Vitamin C Added, Made From Dry Mix, Mainly Sugar
| B | 925–4300 | Orange Breakfast Beverage Made From Frozen Concentrate
| B | 926–1001 | Beverage (Horchata), nfs
| B | 926–1011 | Coconut Beverage
| B | 926–1101 | Oatmeal Beverage
| B | 926–1201 | Sugar Cane Beverage
| B | | Sugar Concentrate Powdered, Not Reconstituted
| B | 929–0010 | Tang, Dry Concentrate
| B | 929–0011 | Fruit Flavored Dry Concentrate (Not Fortified)
| B | 925–7010 | Fluids Replacement Electrolyte Solution
| B | 925–7110 | Calorie Fortifier, Tube Feeding Nutrient
23. Fruit Drinks, Low Calorie, Noncarbonated | B | 924–3200 | Soft Drinks, Noncarbonated, Made From Liquid Concentrates, Imitation Lemonade, Other Fruit Flavors, Low Sugar Content
| B | 924–4100 | Soft Drink, Made From Low Calorie Powdered Mix
| B | 924–4500 | Soft Drink, Made From Low Calorie Powdered Mix with Vitamin C Added
| B | 925–2011 | Cranberry Drinks, Low Calorie
| B | 925–2041 | Fruit Drinks, Low Calorie
| B | 925–2061 | Fruit Punch, Low Calorie
| B | 925–2081 | Grape Drink, Low Calorie
| B | 925–2091 | Lemonade, Unsweetened or Nonnutritive Sweetener
| B | 925–2261 | Lemonade, Low Calorie (Include Made From Dry Mix, Low Sugar)
| B | (925–5) | Fruitades and Drinks, Low Calorie with Vitamin C Added
| B | 925–5011 | Cranberry Juice Cocktail, Low Calorie with Vitamin C Added
| B | 925–5061 | Fruit Punch, Low Calorie with Vitamin C Added
| B | (925–6) | Beverages, Low Sugar, Fruit Flavored, No Vitamin C Added, Ready-to-Drink
| B | 925–6000 | Beverage, Low Sugar, Fruit Flavored
24. Beer and Ale | B | 931 | Beer and Ales
25. Wine | B | 934 | Wines
26. Spirits, Liqueurs, Mixed Drinks | B | 932 | Cordials and Liqueurs
26. Spirits, Liqueurs, Mixed Drinks | B | 933 | Cocktails
| B | 935 | Distilled Liquors
27. Baby Fruit Juice | B | 672 | Baby, Strained and Junior Fruit Juices
28. Baby Food | F | 133 | Baby Foods with Milk
| F | 217 | Baby or Junior Beef
| F | 228 | Baby or Junior Pork, Ham, Meat Sticks
| F | 234 | Baby Veal or Lamb
| F | 247 | Baby or Junior Poultry
| F | 276 | Baby Foods, Combination with Meat, Poultiy, or Fish
| F | 334 | Baby Food-Eggs
| F | 341 | Egg Yolk
| F | 417 | Baby Foods Legumes
| F | 578 | Baby Cereals
| F | 585 | Baby Food Mixtures with Animal Protein
| F | 671 | Fruits and Fruit Mixtures
| F | 673 | Fruits with Cereal
| F | 674 | Fruit Desserts and Puddings
| F | 761 | Dark Green Vegetables
| F | 762 | Deep Yellow Vegetables
| F | 764 | Vegetables Other than Dark Green, Deep Yellow, and Tomato
| F | 766 | Vegetable Mixtures and Meat with Cereal
| F | 767 | Vegetable Mixtures and Liver with Cereal
| F | 765 | Potato Mixtures with Meat

1 F = Food; B = Beverage; D = Drinking Water

2 3–Digit Code = Minor Food Subgroup; 7–Digit Code = Food Item

3 Vegetable juices (Food codes 7513200–7513220, 750203 and 7523550) were coded as Beverages.

4 Unreconstituted dry powered coffees (Food codes 9219100–9219130) and coffee substitutes (9229130–9229140) were coded as foods.