# APPENDIX C ASSUMPTIONS FOR ASSIGNING THE SOURCE OF WATER IN SELECTED SPECIFIC FOOD AND BEVERAGE ITEMS, INCLUDING DRINKING WATER

## A DRINKING WATER

All water reported consumed directly as a beverage (in the "cups of water drunk" question) was coded as "direct tapwater," because we assumed that it came from the household water source.

This assumption was made for the following reasons:

1) Subjects were not asked the location (home, school, work, restaurant, etc.) where the "cups of water" were consumed. We therefore assumed that this water was drunk at home.
2) Subjects were not asked about the source (community reservoir, well, etc.) of the "cups of water" or whether the water was bottled. However, in 1978 only a small proportion of the adult U.S. population used bottled water (1.2% of 5,770 control subjects interviewed for the U.S. National Bladder Cancer Survey [Cantor, K.: unpublished observations; Hartge et al., 1984]). We, therefore, assumed that none (i.e., 0%) of the "cups of water" were from bottled water.

Carbonated water, unsweetened ("club soda," food code number 924–1021) (U.S. Department of Agriculture, 1979) was not a component of direct tapwater. Rather, this food item was considered a beverage.

## B MILKS AND MILK PRODUCTS

1. [underlined: Breast Milk]
  Quantities of breast milk consumed by nursing children were not reported in the 1977–78 NFCS. Total water and tapwater intakes of breast-fed children reported in the tables, therefore, refer to sources other than breast milk.
2. [underlined: Dry Milks]
  Reconstituted dry milks were assumed to contain 100% indirect tapwater.
3. [underlined: Condensed and Evaporated Milks]
  Condensed and evaporated milks were assumed to be diluted 1:1 (by volume) with indirect tapwater unless the Food Code Description (U.S. Department of Agriculture, 1979) specified that the milk was not diluted.
4. [underlined: Fresh Milk, Yogurt, Puddings, Ice Creams, and Cheeses]
  All water contained in these items was assumed to be intrinsic water.
5. [underlined: Milk Used for Preparation of Foods]
  All milk used in cooking or in preparing foods (such as hot chocolate) was assumed to be fresh liquid milk (100% intrinsic water) unless the Food Code Description specified otherwise (U.S. Department of Agriculture, 1979).
6. [underlined: Hot Chocolate]
  Hot chocolate beverages (cocoa) were considered to be made with 50% fresh milk and 50% water, unless otherwise specified.
7. [underlined: Milk with Coffee or Tea]
  "Milk with coffee added" and "milk with tea added" (U.S. Department of Agriculture, 1979) were assumed to contain 75% milk and 25% coffee or tea, respectively.

## C MEAT, POULTRY, AND FISH

1. [underlined: Fresh and Frozen]
  Fresh and frozen cooked meat, poultry, and fish generally were assumed to contain 100% intrinsic water.
2. [underlined: Combination Dishes]
  Stews, casseroles, soups, and gravies were assumed to contain 25%-75% intrinsic water, depending on the Food Code Description (U.S. Department of Agriculture, 1979) specifications of ingredients and whether the food was prepared at home.
3. [underlined: Sandwiches and Frozen Entrees]
  Sandwiches and frozen entrees (including "TV dinners") were assumed to contain 100% intrinsic water.

## D EGGS

1. [underlined: Whole Eggs, Whites, and Yolks]
  Cooked eggs (whole, whites, or yolks), egg salads, and egg sandwiches were assumed to contain 100% intrinsic water.
2. [underlined: Custards and Omelets]
  Custards and omelets were assumed to contain 100% intrinsic water, in accord with standard recipes specifying that milk or cream be added rather than water (Rombauer and Becker, 1975).
3. [underlined: Egg Soups and Powdered Eggs]
  Egg soups and cooked reconstituted powdered eggs were assumed to contain 100% indirect tapwater.

## E LEGUMES

Cooked dry beans and peas were assumed to be half homemade and half canned (that is, they were assumed to have 50% intrinsic water) unless the Food Code Description (U.S. Department of Agriculture, 1979) clearly indicated either a homemade dish or a commercial product.

## F GRAIN PRODUCTS

1. [underlined: Rice, Noodles, Pasta, and Hot Cereals]
  Cooked rice, noodles, pasta, and hot cereals derive 95–98% of their water from indirect tapwater absorbed in cooking. This figure was rounded to 100%.
2. [underlined: Mixed Dishes]
  Mixed dishes (for example, casseroles, pasta with sauce, and pizza) were assigned both an intrinsic water and indirect water content according to the Food Code Description (U.S. Department of Agriculture, 1979) and standard recipes (Rombauer and Becker, 1975).
3. [underlined: Breads, Cakes, and Pastries]
  a. Home prepared baked goods were assigned an intrinsic water and indirect tapwater content according to the Food Code Description (U.S. Department of Agriculture, 1979) and standard recipes (Rombauer and Becker, 1975). The liquid in such baked goods was assumed to be from eggs and fresh milk.
  b. Baked goods not identified as "home prepared" by the Food Code Descriptions (U.S. Department of Agriculture, 1979) were assumed to be commercially manufactured and, therefore, were assumed to contain 100% intrinsic water.
  c. Cakes and cookies made from cake mixes were not identified as such in the Food Code Descriptions (U.S. Department of Agriculture, 1979). We did not attempt to estimate the proportion of "store bought" (i.e., commercial) cakes that actually were made at home (using indirect tapwater) from mixes.

## G FRUITS AND FRUIT JUICES

1. [underlined: Fresh Fruit]
  Fresh fruits were assumed to contain 100% intrinsic water. No attempt was made to estimate water clinging to fruit after washing.
2. [underlined: Dried Fruit]
  Cooked dried fruit was assumed to be a home prepared item and to contain 75% indirect tapwater. Uncooked dried fruit was assumed to contain 100% intrinsic water.
3. [underlined: Cooked/Canned Fruit]
  The food descriptions did not distinguish between canned fruit and cooked fresh fruit. We assumed the cooked/canned fruit to consist mostly of canned fruits. The amount of indirect tapwater added to syrups for home cooked fresh fruit was assumed to be less than 10% of all water for this food category. Thus, all cooked/canned fruits (other than fresh uncooked, dried uncooked, and dried cooked) were assumed to contain 0% indirect tapwater and 100% intrinsic water.
4. [underlined: Orange Juice]
  a. Frozen orange juice was assumed to be reconstituted with 3 volumes indirect tapwater to 1 volume frozen concentrate (which is 58% water by weight before dilution) (U.S. Department of Agriculture, 1963), yielding an 84% tapwater fraction.
  b. "Orange juice, nfs", was assumed to consist entirely of reconstituted frozen orange juice.
5. [underlined: Grapefruit Juice]
  "Grapefruit juice, nfs", was assumed to be 100% canned sweetened grapefruit juice.
6. [underlined: Other Juice]
  "Fruit juice, nfs", was assumed to be composed mostly, but not entirely, of reconstituted frozen orange juice. Other commonly consumed juices were more likely to be fresh or canned. "Fruit juice, nfs", therefore, was assigned an intrinsic water fraction of 25%.

## H VEGETABLES

1. [underlined: Raw Vegetables]
  Raw vegetables were assumed to contain 100% intrinsic water. We did not attempt to account for tapwater clinging to washed vegetables.
2. [underlined: Cooked Vegetables]
  Cooked vegetables were assumed to contain 100% intrinsic water unless cooked in homemade soups, sauces, gravies, casseroles, and the like. We did not estimate the small amounts of water that might have been taken up by the vegetables during cooking or steaming.
3. [underlined: Canned Vegetables]
  Canned vegetables were assumed to contain 100% intrinsic water, which includes water used commercially in canning and packing the vegetables.

## I FATS, OILS, AND DRESSINGS

All foods in this group were assumed to contain 100% intrinsic water except for a small number of homemade salad dressings made with indirect tapwater.

## J SUGARS AND SWEETS

1. [underlined: Sugars and Sweets]
  All sugars and sweets were assumed to contain 100% intrinsic water.
2. [underlined: Gelatin Salads ("Jello^®^")]
  Gelatin salads were assumed to contain 100% indirect tapwater unless they also contained fruits, sour cream, or other ingredients, in which case the indirect tapwater fraction was reduced to 75%.

## K BEVERAGES

1. [underlined: Coffee and Tea]
  a. All coffees except for unreconstituted dry powders were assumed to contain 100% indirect tapwater.
  b. All teas were assumed to contain 100% indirect tapwater except for iced teas made from frozen concentrate (75% indirect tapwater) or purchased as commercial canned drinks (100% intrinsic water).
  c. Herbal teas were grouped with "regular" tea (Camellia sinensis).
2. [underlined: Carbonated Beverages]
  a. All carbonated beverages were assumed to contain 100% intrinsic water.
  b. Unsweetened carbonated water (club soda; Food Code 924–1021) was assumed to contain 100% intrinsic water. Club soda was not included in the calculation of direct tapwater.
3. [underlined: Fruit Drinks]
  Fruit drinks were assumed to contain 100% intrinsic water with the following exceptions:
  a. Reconstituted lemonade, limeade, or orange drink made from frozen concentrate (86% indirect tapwater);
  b. Lemonade made from liquid concentrate (90% indirect tapwater);
  c. Drinks made from reconstituted dry powders (100% indirect tapwater).
4. [underlined: Alcoholic Beverages]
  a. Beer, wine, spirits, hard liquors, and cordials or liqueurs were assumed to contain 100% intrinsic water.
  b. Mixed drinks and cocktails typically made with ice and/or with added water were assumed to contain 25% indirect tapwater. The ethanol content of alcoholic beverages (Cotton, 1981; Rombauer and Becker, 1979) was taken into consideration when calculating the intrinsic water and indirect tapwater contents.

## L SOUPS

1. Soups are grouped with their major (non-water) ingredient: meat, vegetables, grains, potatoes, etc.
2. Canned soups were assumed to be diluted 1:1 (by volume) with indirect tapwater.

## M INFANT, BABY, AND JUNIOR FOODS AND FORMULAS

1. [underlined: Infant Formulas]
  a. "Ready-to-feed" formula was assumed to contain 100% intrinsic water and 0% indirect tapwater.
  b. Formula made from diluted concentrate (1:1 volume: volume) was assumed to contain by weight 43% intrinsic water and 57% indirect tapwater.
  c. Formula made from reconstituted powder was assumed to contain 100% indirect tapwater.
  d. There were no reports of "Infant formula, nfs" (i.e., with the physical form unspecified) in our study sample.
2. [underlined: Baby Cereals]
  Baby cereals were considered to contain 100% intrinsic water because the original data file contained only the quantity of dry cereal used. We assumed that water, formula, milk, or juice used to reconstitute the dry cereal were reported separately.
3. [underlined: Other Baby and Junior Foods]
  All other baby and junior foods and juices were assumed to contain 100% intrinsic water.

## N ICE

Except for ice that was a constituent of mixed alcoholic beverage drinks (see Appendix C, section K.4), we did not estimate the quantity or source of water in ice consumed at home, in restaurants, or elsewhere. Ice was not a separately described food item in the NFCS (USDA, 1979), and study subjects did not report quantities consumed.