# APPENDIX B QUESTIONNAIRE EXCERPT

The following is a reproduction of the question on quantities of water drunk, from Day 1 of the 1977–78 NFCS Food and Beverage Individual Intake Record (U.S. Department of Agriculture, 1984). The same format was used on Days 2 and 3.