# APPENDIX A STATISTICAL ALGORITHMS

## Mean, Variance, Standard Deviation, and Standard Error of the Mean

Statistical calculations were performed using SAS algorithms. The SAS procedure PROC MEANS with the option VARDEF = WDF was employed to calculate weighted means and variances (SAS User's Guide, 1985). SAS algorithms for these are based on the following standard formulas:

1. Mean
  X¯_w_ = (Σ w_i_ X_i_)/(Σ w_i_)
  where X¯_w_ is the (weighted) mean,
  - X_i_ is the value of the ith measurement, and
  - w_i_ is the weight assigned to the ith measurement
2. Variance and Standard Deviation
  S_w_^2^ = ∑_i_ w_i_ (X_i_ - X‾_w_)^2^ / Σ w_i_ - 1
  where S_w_^2^ is the (weighted) variance,
  - S_w_ is the (weighted) standard deviation, and
  - other variables are defined as above.
3. Standard Error of the Mean (SEM)
  S E M = (S_w_)/(sqrt(n))
  where SEM is the standard error of the mean,
  - S_w_ is the square root of the variance or the (weighted) standard deviation, and
  - n is the number of observations.

## Percentile Distribution

The SAS supplemental library procedure PROC PCTL (Harrell, 1983), with the FREQ option, was employed to calculate the weighted percentile distributions, according to the following:

Let X_i_, . . ., X_n_ represent the ordered values of the variable. For the Tth percentile, let P=T/100. Let (n-1)P = j + G, where j is the integer part of (n-1)P and G is the fractional part. The Tth percentile, Y, is defined as:

Y = ( 1 - G ) X_j_ + ( G ) X_j + 1_