# References

1 Swan HJ, Ganz W, Forrester J, Marcus H, Diamond G, Chonette D. Catheterization of the heart in man with use of a flow-directed balloon-tipped catheter. N Engl J Med. 1970;283:447-51. [pmid: 5434111].
2 Mimoz O, Rauss A, Rekik N, Brun-Buisson C, Lemaire F, Brochard L. Pulmonary artery catheterization in critically ill patients: a prospective analysis of outcome changes associated with catheter-prompted changes in therapy. Crit Care Med. 1994;22:573-79. [pmid: 8143466].
3 Cooper AB, Doig GS, Sibbald WJ. Pulmonary artery catheters in the critically ill. An overview using the methodology of evidence-based medicine. Crit Care Clin. 1996;12:777-94. [pmid: 8902371].
4 Connors AF Jr, Speroff T, Dawson NV, Thomas C, Harrell FE Jr, Wagner D, et al. The effectiveness of right heart catheterization in the initial care of critically ill patients. SUPPORT Investigators. JAMA. 1996;276:889-97. [pmid: 8782638].
5 Bender JS, Smith-Meek MA, Jones CE. Routine pulmonary artery catheterization does not reduce morbidity and mortality of elective vascular surgery: results of a prospective, randomized trial. Ann Surg. 1997;226:229-36. [pmid: 9339929].
6 Wilson J, Woods I, Fawcett J, Whall R, Dibb W, Morris C, et al. Reducing the risk of major elective surgery: randomised controlled trial of preoperative optimisation of oxygen delivery. BMJ. 1999;318:1099-103. [pmid: 10213716].
7 Valentine RJ, Duke ML, Inman MH, Grayburn PA, Hagino RT, Kakish HB, et al. Effectiveness of pulmonary artery catheters in aortic surgery: a randomized trial. J Vasc Surg. 1998;27:203-11. [pmid: 9510275].
8 Sibbald WJ, Keenan SP. Show me the evidence: a critical appraisal of the Pulmonary Artery Catheter Consensus Conference and other musings on how critical care practitioners need to improve the way we conduct business. Crit Care Med. 1997;25:2060-2063. [pmid: 9403760].
9 Pulmonary Artery Catheter Consensus conference: consensus statement. Crit Care Med. 1997;25:910-925. [pmid: 9201042].
10 Dalen JE, Bone RC. Is it time to pull the pulmonary artery catheter?. JAMA. 1996;276:916-18. [pmid: 8782643].
11 Polanczyk CA, Rohde LE, Goldman L, Cook EF, Thomas EJ, Marcantonio ER, et al. Right heart catheterization and cardiac complications in patients undergoing noncardiac surgery: an observational study. JAMA. 2001;286:309-14. [pmid: 11466096].
12 Monnet X, Richard C, Teboul JL. The pulmonary artery catheter in critically ill patients. Does it change outcome?. Minerva Anestesiol. 2004;70:219-24. [pmid: 15173699].
13 Bernard GR, Sopko G, Cerra F, Demling R, Edmunds H, Kaplan S, et al. Pulmonary artery catheterization and clinical outcomes: National Heart, Lung, and Blood Institute and Food and Drug Administration Workshop Report. Consensus Statement. JAMA. 2000;283:2568-72. [pmid: 10815121].
14 Binanay C, Califf RM, Hasselblad V, O'Connor CM, Shah MR, Sopko G, et al. Evaluation study of congestive heart failure and pulmonary artery catheterization effectiveness: the ESCAPE trial. JAMA. 2005;294:1625-33. [pmid: 16204662].
15 Wheeler AP, Bernard GR, Thompson BT, Schoenfeld D, Wiedemann HP, deBoisblanc B, et al. Pulmonary-artery versus central venous catheter to guide treatment of acute lung injury. N Engl J Med. 2006;354:2213-24. [pmid: 16714768].
16 Eagle KA, Berger PB, Calkins H, Chaitman BR, Ewy GA, Fleischmann KE, et al. ACC/AHA guideline update for perioperative cardiovascular evaluation for noncardiac surgery---executive summary a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Update the 1996 Guidelines on Perioperative Cardiovascular Evaluation for Noncardiac Surgery). Circulation. 2002;105:1257-67. [pmid: 11889023].
17 American Society of Anesthesiologists Task Force on Pulmonary Artery Catheterization. Practice guidelines for pulmonary artery catheterization: an updated report by the American Society of Anesthesiologists Task Force on Pulmonary Artery Catheterization. Anesthesiology. 2003;99:988-1014. [pmid: 14508336].
18 Harvey S, Stevens K, Harrison D, Young D, Brampton W, McCabe C, et al. An evaluation of the clinical and cost-effectiveness of pulmonary artery catheters in patient management in intensive care: a systematic review and a randomised controlled trial. Health Technol Assess. 2006;10:1-150.
19 Shah MR, Hasselblad V, Stevenson LW, Binanay C, O'Connor CM, Sopko G, et al. Impact of the pulmonary artery catheter in critically ill patients: meta-analysis of randomized clinical trials. JAMA. 2005;294:1664-70. [pmid: 16204666].
20 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Medical Decision Making. 1991;11:88-94. [pmid: 1907710].
21 Balk E, Chung M, Lichtenstein A, Chew P, Kupelnick B, Lawrence A, et al. Effects of omega-3 fatty acids on cardiovascular risk factors and intermediate markers of cardiovascular disease. Evidence Report/Technology Assessment No. 93 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022). AHRQ Publication No. 04-E010-2. Rockville, MD. Agency for Healthcare Research and Quality. 2004.
22 Clinical Practice Guidelines for Chronic Kidney Disease: Evaluation, Classificaiton, and Stratification. Am J Kid Dis. 2002;39.
23 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-88. [pmid: 3802833].
24 Higgins JP, Whitehead A, Turner RM, Omar RZ, Thompson SG. Meta-analysis of continuous outcome data from individual patients. Stat Med. 2001;20:2219-41. [pmid: 11468761].
25 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in metaanalyses. BMJ. 2003;327:557-60. [pmid: 12958120].
26 English IC, Frew RM, Pigott JF, Zaki M. Percutaneous catheterisation of the internal jugular vein. Anaesthesia. 1969;24:521-31. [pmid: 5350391].
27 Berton C, Cholley B. Equipment review: new techniques for cardiac output measurement--oesophageal Doppler, Fick principle using carbon dioxide, and pulse contour analysis. Crit Care. 2002;6:216-21. [pmid: 12133181].
28 De Maria AN, Raisinghani A. Comparative overview of cardiac output measurement methods: has impedance cardiography come of age?. Congest Heart Fail. 2000;6:60-73. [pmid: 12029189].
29 Berlauk JF, Abrams JH, Gilmour IJ, O'Connor SR, Knighton DR, Cerra FB. Preoperative optimization of cardiovascular hemodynamics improves outcome in peripheral vascular surgery. A prospective, randomized clinical trial. Ann Surg. 1991;214:289-97. [pmid: 1929610].
30 Bonazzi M, Gentile F, Biasi GM, Migliavacca S, Esposti D, Cipolla M, et al. Impact of perioperative haemodynamic monitoring on cardiac morbidity after major vascular surgery in low risk patients. A randomised pilot trial. Eur J Vasc Endovasc Surg. 2002;23:445-51. [pmid: 12027474].
31 Guyatt G. A randomized control trial of right-heart catheterization in critically ill patients. Ontario Intensive Care Study Group. J Intensive Care Med. 1991;6:91-95. [pmid: 10147952].
32 Harvey S, Harrison DA, Singer M, Ashcroft J, Jones CM, Elbourne D, et al. Assessment of the clinical effectiveness of pulmonary artery catheters in management of patients in intensive care (PAC-Man): a randomised controlled trial. Lancet. 2005;366:472-77. [pmid: 16084255].
33 Isaacson IJ, Lowdon JD, Berry AJ, Smith RB III, Knos GB, Weitz FI, et al. The value of pulmonary artery and central venous monitoring in patients undergoing abdominal aortic reconstructive surgery: a comparative study of two selected, randomized groups. J Vasc Surg. 1990;12:754-60. [pmid: 2243411].
34 Pearson KS, Gomez MN, Moyers JR, Carter JG, Tinker JH. A cost/benefit analysis of randomized invasive monitoring for patients undergoing cardiac surgery. Anesth Analg. 1989;69:336-41. [pmid: 2505641].
35 Rhodes A, Cusack RJ, Newman PJ, Grounds RM, Bennett ED. A randomised, controlled trial of the pulmonary artery catheter in critically ill patients. Intensive Care Med. 2002;28:256-64. [pmid: 11904653].
36 Richard C, Warszawski J, Anguel N, Deye N, Combes A, Barnoud D, et al. Early use of the pulmonary artery catheter and outcomes in patients with shock and acute respiratory distress syndrome: a randomized controlled trial. JAMA. 2003;290:2713-20. [pmid: 14645314].
37 Sandham JD, Hull RD, Brant RF, Knox L, Pineo GF, Doig CJ, et al. A randomized, controlled trial of the use of pulmonary-artery catheters in high-risk surgical patients. N Engl J Med. 2003;348:5-14. [pmid: 12510037].
38 Schultz RJ, Whitfield GF, LaMura JJ, Raciti A, Krishnamurthy S. The role of physiologic monitoring in patients with fractures of the hip. J Trauma. 1985;25:309-16. [pmid: 3989888].
39 Shoemaker WC, Appel PL, Kram HB, Waxman K, Lee TS. Prospective trial of supranormal values of survivors as therapeutic goals in high-risk surgical patients. Chest. 1988;94:1176-86. [pmid: 3191758].
40 Joyce WP, Provan JL, Ameli FM, McEwan MM, Jelenich S, Jones DP. The role of central haemodynamic monitoring in abdominal aortic surgery. A prospective randomised study. Eur J Vasc Surg. 1990;4:633-36. [pmid: 2279574].
41 Shoemaker WC, Kram HB, Appel PL, Fleming AW. The efficacy of central venous and pulmonary artery catheters and therapy based upon them in reducing mortality and morbidity. Arch Surg. 1990;125:1332-37. [pmid: 2222172].
42 Ioannidis JP, Ntzani EE, Trikalinos TA, Contopoulos-Ioannidis DG. Replication validity of genetic association studies. Nat Genet. 2001;29:306-9. [pmid: 11600885].
43 Kelso LA. Complications associated with pulmonary artery catheterization. New Horiz. 1997;5:259-63. [pmid: 9259340].
44 Matthay MA, Chatterjee K. Bedside catheterization of the pulmonary artery: risks compared with benefits. Ann Intern Med. 1988;109:826-34. [pmid: 3056159].
45 Sladen A. Complications of invasive hemodynamic monitoring in the intensive care unit. Curr Probl Surg. 1988;25:69-145. [pmid: 3280251].
46 Patel C, Laboy V, Venus B, Mathru M, Wier D. Acute complications of pulmonary artery catheter insertion in critically ill patients. Crit Care Med. 1986;14:195-97. [pmid: 3943335].
47 Mermel LA, Maki DG. Infectious complications of Swan-Ganz pulmonary artery catheters. Pathogenesis, epidemiology, prevention, and management. Am J Respir Crit Care Med. 1994;149:1020-1036. [pmid: 8143037].
48 Liu C, Webb CC. Pulmonary artery rupture: serious complication associated with pulmonary artery catheters. Int J Trauma Nurs. 2000;6:19-26. [pmid: 10642409].
49 Iberti TJ, Fischer EP, Leibowitz AB, Panacek EA, Silverstein JH, Albertson TE. A multicenter study of physicians' knowledge of the pulmonary artery catheter. Pulmonary Artery Catheter Study Group. JAMA. 1990;264:2928-32. [pmid: 2232089].
50 Burns D, Burns D, Shively M. Critical care nurses' knowledge of pulmonary artery catheters. Am J Crit Care. 1996;5:49-54. [pmid: 8680493].
51 Karanikas ID, Polychronidis A, Vrachatis A, Arvanitis DP, Simopoulos CE, Lazarides MK. Removal of knotted intravascular devices. Case report and review of the literature. Eur J Vasc Endovasc Surg. 2002;23:189-94. [pmid: 11914003].
52 Bossert T, Gummert JF, Bittner HB, Barten M, Walther T, Falk V, et al. Swan-Ganz catheter-induced severe complications in cardiac surgery: right ventricular perforation, knotting, and rupture of a pulmonary artery. J Card Surg. 2006;21:292-95. [pmid: 16684066].
53 Boyd KD, Thomas SJ, Gold J, Boyd AD. A prospective study of complications of pulmonary artery catheterizations in 500 consecutive patients. Chest. 1983;84:245-49. [pmid: 6884097].
54 Damen J, Bolton D. A prospective analysis of 1,400 pulmonary artery catheterizations in patients undergoing cardiac surgery. Acta Anaesthesiol Scand. 1986;30:386-92. [pmid: 3766094].
55 Kearney TJ, Shabot MM. Pulmonary artery rupture associated with the Swan-Ganz catheter. Chest. 1995;108:1349-52. [pmid: 7587440].
56 Lopez-Sendon J, Lopez de SE, Gonzalez MI, Coma-Canella I, Ramos F, Dominquez F, et al. Right ventricular infarction as a risk factor for ventricular fibrillation during pulmonary artery catheterization using Swan-Ganz catheters. Am Heart J. 1990;119:207-9. [pmid: 2296867].
57 Shah KB, Rao TL, Laughlin S, El-Etr AA. A review of pulmonary artery catheterization in 6,245 patients. Anesthesiology. 1984;61:271-75. [pmid: 6476435].