# Discussion

As described in the introduction and in the narrative reviews in response to questions 1 and 2 (describing the available technologies to assess cardiac output and manage volume status, and describing the specific indications for pulmonary artery catheter [PAC] use), PAC is an important tool for management of select patients in intensive care settings. However, since its introduction, PAC use has propagated to a wide range of patients in multiple settings. By helping to quantify, and thus to manage cardiac output and volume status, PAC is commonly used to guide therapy and is seen as beneficial to the patients and clinicians. However, the benefits of the routine use of PAC for broad groups of patients have not been substantiated by randomized controlled trials (RCTs) in the setting of risks of adverse events due to this invasive intervention.

Overall, the evidence suggests no benefit of the routine use of PAC in the ICU to large groups of patients within trials. The evidence also documents a wide range of risks of PAC use; though adverse events are relatively rare and serious adverse events are very rare. Since 1985, 16 randomized trials have compared routine PAC use to either no PAC or to central venous pressure (CVP) monitoring. With the exception of the first reported trial (38), the trials consistently found no difference in mortality or length of stay (LOS) in the intensive care unit (ICU) or hospital. The summary odds ratio (OR) of death was 1.03 (95% confidence interval [CI] 0.9, 1.2), the difference in hospital LOS was +0.3 (95% CI, -0.4, 1.0; favoring no PAC) days, and the difference in ICU LOS was 0 (95% CI −0.5, 0.5) days.

The studies were clinically heterogeneous. In addition to the two different types of controls (no invasive monitoring and CVP monitoring), studies were performed in a range of ICU settings, in patients with a wide range of both medical and surgical morbidities, across various countries, over a long time period during which the standards of ICU care have changed considerably, and in patients with different underlying risks of clinical events. Despite the large degree of clinical heterogeneity among the studies the studies were statistically homogenous in their results – almost all found no clinically or statistically significant differences. This consistency of results in the setting of diverse studies adds credibility to the conclusion that in trials, patient outcomes are similar regardless of use of PAC. The average age of patients in studies was generally over 60 years. It is likely that nearly half the patients across studies would be Medicare-eligible, based on age. Thus, the patients included in studies of PAC are fairly-well applicable to the Medicare population. However, it is possible that differences in the benefit of PAC are hidden within the studies. No study evaluated the how the effect of PAC varied with patient age and no conclusions could be drawn from comparison across studies based on average patient age.

Importantly, most trials generally either explicitly or implicitly excluded patients for whom the treating physician determined that PAC was absolutely necessary. However, the studies used a broad range of eligibility criteria, making it difficult to assess exactly how applicable the individual trials and the totality of the studies are for a given group of patients. All; but two of the 16 trials reported excluding patients who were at “high risk” – variously defined as requiring inotropic drugs, having severe medical conditions, or unstable – or for whom PAC was an ethical imperative, mandatory, indicated, or there was lack of physician equipoise regarding PAC use. Among trials that reported how many patients were excluded for stated reasons, between 0.5 and 52 percent of patients were thus excluded (with a median of 2 percent). Only one trial of about 200 patients explicitly limited the studied participants to those considered to “requir[e] a PAC,” though one patients was still excluded for ethical reasons.(34) Only one trial (of patients at high risk of dying after surgery) apparently did not exclude patients with “too high” a risk without PAC.[Shoemaker 88 90], but instead excluded patients who were not sufficiently ill to require intensive monitoring. Overall, then, the findings of these trials can be applied only to patients who would be enrolled in a trial on the basis of their not requiring PAC for some reason. For the most part, the studies evaluated the routine use of PAC in patients who were deemed to not necessarily need PAC, instead of attempting to determine whether PAC may be of value for particular patients for whom it can be hypothesized that the intervention would be of particular value. It remains unknown how much, if at all, the sickest, potentially highest risk patients benefit from PAC compared to noninvasive monitoring. Because of this the evidence provides only an incomplete answer to the question (Key Question 3) of whether therapeutic management of cardiac output and volume status based on pulmonary artery catheter monitoring in critical care settings leads to improved patient outcomes compared to noninvasive and less invasive techniques.

A potential threat to the validity of these studies is crossover of interventions. Only 9 of 16 studies reported rates of crossover (patients assigned to control, but received PAC); of these the crossover rates were relatively low (less than 10 percent) in most, but very high (47 and 64 percent) in two small studies. While it is possible that crossover of patients dampened any effects of PAC (by making it more likely that event rates were similar in the two arms) the low crossover rates in the larger studies limits the overall effect of crossover on the summary results and thus the conclusions.

Most of the trials also reported some data on relative rates of various medical morbidities; primarily cardiovascular, pulmonary, and renal events. These morbidities related to the underlying disease states of the patients (i.e., the reasons that they required ICU management), not specifically due to adverse events due to invasive monitoring. The findings across studies were highly inconsistent with several studies finding no differences in event rates and the remaining studies equally distributed among those that found higher event rates in those with PAC monitoring and those with higher rates in the control arms. There was no easily discernable pattern based on underlying medical or surgical condition, setting, time period (year), specific medical morbidity, or other factors. Overall across studies, about the same rate of medical morbidities were reported among patients with PAC as without PAC.

Only three trials reported on duration of ventilation. All found no statistically significant difference between PAC and no PAC, although one study found that patients with PAC had a much greater duration of ventilation than those without PAC (35 vs. 6 hours). The four studies that evaluated quality of life (or disease severity) had differing findings. A large well-conducted trial found greater improvement in the Minnesota Living with Heart Failure questionnaire at 1 month, but not 6 months, with PAC; but no differences in other measures of patient symptoms. In contrast, a small trial found that APACHE scores were statistically significantly worse after PAC use than without PAC at discharge from the intensive care unit; however, the APACHE score was not designed, nor has it been validated, for longitudinal testing. Two studies that used the Systemic Organ Failure Assessment (SOFA) score found no difference between interventions.

The use of PAC provides only diagnostic information, which if used appropriately can help to guide therapeutic management of shock and other conditions requiring hemodynamic monitoring. The efficacy of the test to provide an intervention to improve outcome is based on the accuracy of interpretation as well as whether the information is acted upon appropriately. The questions of interest pertain to the clinical benefit of using PAC in intensive care settings, as opposed to accuracy of diagnosis. In Fryback's and Thornbury's model, the evidence considered here are at Level 5, evaluating “patient outcome efficacy,” how using the diagnostic tool impacts on clinical benefits (20). It is possible that the lack of benefit from PAC use among these studies is related to ineffective or improper changes in management strategy based on PAC data rather than to a lack of potential benefit of the PAC data. None of the studies used a specific protocol for use of the PAC data, though Wheeler 2006 (15) did set targets for fluid and circulation maintenance based in part on PAC or CVP data. Three studies (including the Wheeler study) did report significantly greater use of fluids, vasoactive drugs, and/or diuretics, but even these found no clinical benefits overall. Nevertheless, it is reasonable to contend that improvements in effective management strategies for critically ill patients may result in clinical benefits from PAC placement in the future. However, currently, given the ways that PAC data are acted upon, as evidenced from the published trials, the value of PAC in broadly defined populations of intensive care patients is unproven.

Given the lack of evidence of benefit for the routine use of PAC across large groups of patients, the adverse events related to PAC play a particularly important role in its evaluation. As listed in Table 10, a large number of clinically important, and sometimes disastrous, adverse events are known to occur due to the risks involved in inserting, maintaining, and removing a PAC. While some of the adverse events may often be relatively easy to treat or are self-limited (e.g., arrhythmias, hemorrhage, infection), many of the adverse events are life-threatening or require emergency surgery or interventional radiology procedures. Clinically significant arrhythmias, carotid artery punctures, clinically important septicemia, pneumothorax, hemothorax, and pulmonary embolism each occurred in studies between about 0.5 and 3 percent of patients. An important caveat, though, is that the data on the relative rates between PAC placement and CVP placement or noninvasive monitoring of complications (or adverse events) that might be attributed to central line placement have not been adequately reported. Few comparative studies reported event rates for both arms and no trial clearly reported events attributed to CVP placement. Thus it is in fact difficult to judge the balance between lack of benefit of PAC in populations of patients (where benefits to individual patients may thus be rare) with rare complications in individual patients.

Among the trials and large cohort studies reviewed, only one death “due to PAC” was reported among up to almost 17,000 patients (depending on whether one counts studies that did not mention PAC-related deaths). However, the manufacturer and user facility device experience database gathered by the Food and Drug Administration (FDA) has reports of 48 deaths associated with PAC between 1993 and 1999 (48). Of course, these analyses only evaluate those deaths that were determined to caused by PAC, correctly or not, and does not include other deaths that may have in fact ultimately have been due to PAC placement.

Future research is needed to determine which patients, if any, in what settings and circumstances, may benefit. In general the studies so far have excluded patients for whom the treating physician felt that it was not ethically appropriate to withhold PAC. Patients who are in cardiogenic shock or on inotropic therapy have generally been excluded. Other patients who may potentially benefit from the placement of PAC are those with advanced heart failure for whom a clinical assessment of volume status is not possible (e.g., obese patients), patients in whom there is a discrepancy in clinical assessment and patient symptomatology, and patients with hypotension and pulmonary congestion. However, RCTs may not be possible in these patient populations as treating physicians would not be willing to randomize them. Nevertheless, as best as possible, given the limitations on who can be enrolled, future RCTs should focus on specific populations of patients who might benefit from PAC, as opposed to additional trials of patients for whom PAC use is only reasonable or of possible value. At this point, observational studies may be the only practical way to answer the question of whether the patients who are believed to need PAC really do benefit from the intervention. However, any such study would need to be excellent quality and use rigorous methods to adjust for confounding differences among those patients who receive PAC or not. Preferably, such studies should use multiple methods for adjusting for confounders and baseline risks, performing sensitivity analyses, to strengthen their conclusions. Any future studies should continue to focus primarily on clinical benefits and harms as short-term intermediate outcomes are inadequate surrogates for clinically important outcomes. The methods section of the ESCAPE trial (14) states that “a concurrent PAC registry was established to characterize hospitalized patients receiving PACs considered to be required during heart failure management.” It is hoped that this registry will provide more insight into this population; however, unless the registry is including patients who are thought to require PAC, but do not in fact receive it, and the analysis successfully accounts for baseline differences between these patients and those receiving PAC, it is likely that the ESCAPE registry will only incompletely assess the relative value of PAC use in this population. Only two studies have reported on subgroup analyses. Both found that there were no statistically significant differences in mortality with or without PAC, regardless of subgroup; however, neither study had enrolled enough patients for these analyses to rule out true differences across subgroups. Patient level metaanalysis of these two studies and other large trials may be helpful in finding any groups of patients who are more likely to benefit from PAC use. In this type of analysis, the patient-level data from all included studies are combined allowing more refined analyses than are possible from study-level metaanalyses of reported data.

As the only proven way to assess hemodynamic data, it is important that we do not abolish PAC completely but use it judiciously. It is important for any new trials looking at hemodynamic data (to assess newer therapies or for other technology to assess hemodynamics) to consider a central core lab to evaluate the accuracy of readings as well as provide treatment algorithms to standardize intervention based on the hemodynamic data. The available evidence does not consider many special circumstances where there may be reason to suppose that PAC is of value. However, the evidence does support the conclusion that in patients for whom PAC use is not deemed absolutely necessary, the routine use of PAC does not improve long-term clinical outcomes. At the same time, PAC use imposes uncommon, but identifiable, risks of adverse events. Physicians should be educated about the risks and benefits of PAC-directed therapy to allow for judicious decisions about its use on an individual basis.