# Results

## Question 1 What types of devices and techniques are currently used to assess cardiac output and manage volume status in critical care settings (including operating and recovery rooms)?

Question 1 has been answered based on a narrative review of the literature.

Measurement of the cardiac output is an essential part of any hemodynamic study. An ideal technique for cardiac output measurement should be accurate, reproducible, easy to perform, cost-effective, able to perform in varied settings and should not be associated with any excess morbidity or mortality to the patients. The general technique and uses of PAC has been described in the introduction; this section will briefly describe various devices that utilize invasive or noninvasive techniques and are used to monitor hemodynamic status in critical care settings. The invasive techniques include:

- PAC using various methods based on (a) the Fick Principle, (b) the indicator dye dilution technique and (c) thermodilution method
- Central venous pressure (CVP) catheter
- Transesophageal Doppler measurement
- Pulse contour analysis methods

The noninvasive techniques include:

- Echocardiography and Doppler echocardiography
- Impedance cardiography
- Partial CO_2_ consumption/Inert gas exchange
- Others such as nuclear imaging and left ventriculography

### Invasive technologies

#### Various methods that utilize PAC

The method using Fick principle estimates the cardiac output as the ratio between oxygen consumption and arteriovenous difference in oxygen. The Fick principle involves measuring VO_2_ consumption per minute using a spirometer and a CO_2_ absorber, the oxygen content of mixed venous blood (pulmonary artery), and oxygen content of peripheral arterial blood. Adolf Fick in 1870 postulated that the oxygen uptake in the lungs is entirely transferred to the blood. However this estimation is accurate only when the hemodynamic status is sufficiently stable to allow constant gas diffusion during the mean transit time through the lungs. The Fick principle has also been applied to any gas diffusing through the lungs and this also has been adapted as a noninvasive technique.

The indicator dye method first proposed by Stewart in 1890, and subsequently modified by Hamilton, which utilizes addition of a known concentration of dye indicator to mix with blood. The final dye concentration is determined using a densitometer. With continuous sampling, a time-concentration or indicator dilution curve can be plotted and cardiac output is estimated using the Stewart Hamilton equation.

Thermodilution method applies the dye dilution principle using temperature as the indicator. A known quantity of solution at a known temperature is injected rapidly into the right atrium and the temperature of the blood admixed with the solution is measured using a thermistor in the PAC in the pulmonary artery. The time-temperature curve is plotted and the cardiac output is calculated using a modified Stewart Hamilton equation. Continuous thermodilution uses a 10 cm long thermal filament to emit energy pulses, and the pulmonary artery temperature changes are identified using a computerized algorithm using the thermodilution washout curve and applying the modified Stewart Hamilton equation. The cardiac output is averaged over 30 to 60 seconds and displayed as a continuous reading.

#### Central venous pressure (CVP) catheter

CVP was first described in 1969 (26) and is frequently used for measuring right atrial pressure and estimation of the intravascular volume status. CVP is inserted through a major vein in the neck or chest, placed in superior vena cava or right atrium and water manometer or electronic transducer attached to the catheter monitors the pressure. The common indications for CVP include: major operative procedures, intravascular volume assessment in acute kidney failure, inadequate peripheral access, frequent venous sampling, venous access for vasoactive or chronic drug administration, rapid infusion of intravenous fluids, and other uses such as insertion of transvenous pacing wires and for plasmapheresis or hemodialysis. The right atrial pressures can be estimated using CVP measurements and circulatory status can be manipulated. However in critically ill patients with compromised cardiovascular status, such estimations of right heart pressures do not correlate well with PAOP; thus making CVP a less favored device to monitor circulation status.

#### Transesophageal Doppler measurement

Transesophageal Doppler estimates continuous noninvasive and real time monitoring of cardiac output from measurements of aortic flow velocities. The device consists of a continuous wave Doppler transducer mounted at the tip of a transesophageal probe that is placed in the midesophagus directed at the descending aorta. The probe is connected to a monitor that displays the aortic flow velocity profiles from the spectral analysis of the Doppler signal. Bedside measurement of the crosssectional area of the descending aorta can be performed either by using transesophageal echocardiography or estimated based on the patient's age, weight, and height by a nomogram incorporated to the transesophageal Doppler device. The stroke volume is then calculated from the maximum aortic velocity-time integral and the aortic crosssectional area to obtain blood flow volume per heartbeat. Cardiac output is estimated from the heart rate and stroke volume, which in turn is based on assumptions of accurate measurements of aortic flow velocity profile, estimated crosssectional area of the aorta, and variations in the descending aortic blood flow. However this device does not provide complete estimates of cardiac pressures. The device use is limited to patients who are unconscious, well sedated, or anesthetized and has the potential side effect of trauma to the esophagus.

#### Pulse contour methods

The pulse contour analysis estimates cardiac output measurement indirectly that is computed from pressure pulsation based on the classic Windkessel model described by Otto Frank in 1899. The majority of the pulse contour methods are explicitly or implicitly based on this model and estimate beat-to-beat stroke volume. They relate an arterial pressure or pressure difference to a flow or volume change that are derived from a major peripheral artery. Currently available pulse contour methods include PiCCO (Pulsion), PulseCO (LiDCO) and Modelflow (TNO/BMI). All three pulse contour methods use an invasively measured arterial blood pressure that needs to be calibrated. The calibration generally involves injecting cold saline solution into a central vein and temperature changes are measured using a thermistor on the arterial end (other techniques are also used). Output of these pulse contour systems is calculated on a beat-to-beat basis, and the data is averaged over 30 seconds (27). While this technique provides continuous measurement of cardiac output, records arterial and central venous pressures, and calculates many hemodynamic variables its usefulness is limited to patients in sinus rhythm.

### Noninvasive technologies

Noninvasive cardiac imaging can be utilized to give a reasonable estimate of cardiac output and function even though specific pressures within cardiac chambers cannot be recorded.

#### Echocardiography and Doppler echocardiography

Echocardiography utilizes ultrasound techniques to produce a two or three-dimensional view of the heart. The ultrasound images cardiac structures including the valve structure and function, valvular regurgitation, the morphology of the chambers, and any abnormal communication between the right and left side of the heart. It also measures cardiac output and left ventricular ejection fraction. Echocardiography is usually used with Doppler ultrasound to estimate the flow related measurements. Limitations include poor acoustic window and poor transmission of ultrasound in artificially ventilated patients.

Transthoracic Doppler measurement monitors cardiac output similar to trans-esophageal Doppler, but utilizes a noninvasive technique. The device consists of a continuous wave Doppler transducer mounted at the tip of a transthoracic probe that is placed in the sternal notch directed at the ascending aorta. Its noninvasive technique makes it useful to monitor cardiac output in conscious patients. Limitations of this device include lack of reliable estimates of cardiac output due to difficulty in maintaining a constant angle between the ascending aorta and the probe. The device gives only indirect estimates of vascular or cardiac pressures.

#### Impedance cardiography

Hemodynamic measurements of cardiac output using thoracic electrical bioimpedance (TEB) devices are a form of plethysmography that relates changes in thoracic electrical conductivity to changes in thoracic aortic blood volume and blood flow. TEB measures cardiac output, cardiac index, stroke volume, and ejection fraction. TEB utilizes the principle that resistance to electrical current in the thorax varies in relation to the amount of blood in the aorta. It works by introducing a low voltage alternating current between sets of electrodes or leads that are placed on the skin surface over the thorax. The difference between the voltage that is introduced by the device and that which the device senses from the thorax indicates the amount of resistance or impedance that the electrical current encounters. The impedance, in conjunction with electrocardiographic results and an estimation equation for stroke volume estimates cardiac output from which other cardiac measures may also be computed (28). Cardiac index is one other cardiac parameter that can be calculated from bioimpedance measurements. Currently, some of the electrical bioimpedance devices in the marketplace are Bio Z® (Cardiodynamics, Inc.), TEBCO (Thoracic Electrical Bioimpedance Cardiac Output, Hemo Sapiens, Inc.).

#### Partial CO_2_ consumption/Inert gas exchange

Inert gas rebreathing, also known as foreign gas rebreathing, utilizes the uptake of an indicator gas from the lungs for measuring cardiac output. Foreign gases used in the rebreathing method are physiologically inert, blood soluble gases such as acetylene, carbon dioxide, and nitrous oxide. This technique entails the use of a closed rebreathing system where a very small amount of an inert gas is inhaled from a rebreathing bag. Patients breathe through a mouthpiece with the nasal passages closed by a nasal clip. The uptake these gases are measured continuously and simultaneously at the mouthpiece by a photoacoustic gas analyzer in the device. The solubility of these gases in the blood and the rates at which they are absorbed in the lungs give an estimate of the pulmonary blood flow. Measurement of the concentration curve of the inert gas and calculation of the washout rate with a respiratory mass spectrometer or infrared photoacoustic gas analyzer estimates the cardiac output. Higher cardiac output results in a higher disappearance rate measured as the slope of the gas curve.

Currently available devices include the NICO (Novametrix) system, a noninvasive device that applies Fick's principle on CO_2_, and the Innocor TM (Innovision) that uses oxygen-enriched mixture containing two foreign inert gases typically 0.5% nitrous oxide (N_2_O) and 0.1% sulphur hexafluoride (SF_6_). Initial clinical trials have evaluated the agreement between inert gas rebreathing and other techniques such as thermodilution. However, these clinical trials were small, mainly focused on specific patient groups. The limitations of these devices include changing patterns of ventilation that may have an unpredictable influence on measurements and lack of measurement of vascular pressures.

## Question 2 What are the specific indications for pulmonary artery catheter placement in critical care settings?

Question 2 has been answered based on a narrative review of the literature. The general technique and uses of PAC has been described in the introduction chapter and under question 1. PAC can be an aid to diagnosis as well as guide therapy. The specific indications for PAC in critical care settings are tabulated here.

Table 1 Specific indications for PAC in critical care settings

Diagnosis and Evaluation; - Differential diagnosis of shock; - Cardiogenic shock; - Septic shock; - Hypovolemic shock; - Evaluation of pulmonary edema; - Cardiogenic pulmonary edema; - Non-cardiogenic pulmonary edema; - Etiology of cardiac failure; - Restrictive pericarditis; - Constrictive pericarditis; - Cardiac tamponade; - Evaluation of cardiac structures; - Valvular diseases; - Intracardiac shunts; - Evaluation of shock in setting of acute myocardial infarction (AMI); - Evaluation of primary pulmonary hypertension; - Evaluation in renal failure to assess volume status
Therapeutic Management; - Guide therapy in advanced heart failure; - Guide therapy in complicated AMI; - Treatment of primary pulmonary hypertension; - Adjust hemodynamics during major surgery; - Management of patients with multiorgan failure; - Ventilator management; - Guide pharmacologic therapy (vasopressors, inotropes, and vasodilators); - Guide fluid management (major bleed, burns, sepsis, and acute kidney failure)

## Question 3 Does therapeutic management of cardiac output and volume status based on pulmonary artery catheter monitoring in critical care settings lead to improved patient outcomes compared to noninvasive and less invasive techniques?

A total of 16 trials (5;7;8;14;15;29-40) met eligibility criteria of studies that examined whether therapeutic management based on PAC monitoring led to improved patient outcomes compared to noninvasive and less-invasive techniques. Fifteen trials reported data on mortality, 13 of which also reported data on the length of hospital stay and/or on the length of ICU stay. Eleven trials reported comparative rates of various medical morbidities.

The trials were clinically heterogeneous. The articles were published between 1985 and 2006. They differed widely in their design, eligibility criteria and settings, resulting in very different groups of patients being analyzed (Table 2). Nine studies compared PAC to no PAC, seven compared PAC to CVP. Five trials were conducted in medical or general intensive care units, nine in surgical intensive care units, one in both medical and surgical intensive care units, and one in a cardiac care unit. Only four studies included a broad range of patients, not restricted to a specific set of surgeries or medical conditions (2 medical or general units (32;35), the medical and surgical units study (31), and one surgical unit study (39;41)). Only Harvey 2005 and Rhodes 2002 explicitly included patients who were deemed to require PAC (“should be managed with a PAC”; “requiring a PAC”) by their treating physicians (32;35). However, Rhodes 2002 excluded patients “for which the standard of practice… is to supra-normalize their circulation perioperatively with the use of PAC” and one patient was excluded because their physician believed it was unethical to withhold PAC. And Harvey 2005 excluded patients for whom there was “lack of equipoise from [their] treating physician.” As described in their eligibility criteria, studies tended to focus on populations that were clinically ill, but not on populations for whom intensive, invasive hemodynamic monitoring was thought to be of particular value; 11 of the 16 studies excluded patients for whom PAC was deemed necessary or who were at high risk (5;7;14;15;29-31;33;35;36;40). Across the studies that reported data, between 0.5 and 52 percent of potentially eligible patients were excluded because presence of severe medical conditions or physician determination that withholding PAC would be inappropriate or unethical (though most studies did not report numbers of excluded patients); among the seven studies that reported data, a median of 23 percent of patients were excluded for these reasons. Most studies excluded patients for whom PAC may be of most value (e.g., post-myocardial infarction, valvular disease, poorly compensated congestive heart failure). Pearson 1989 reassigned patients for whom the anesthesiologist judged that PAC was indicated to separate cohorts who received PAC (34).

Table 2 Settings and populations of randomized trials of pulmonary artery catheterization

Study, Year | Setting | Major eligibility criteria (Percent of recruited patients excluded^*^) | Hemodynamic status | Patients' diagnoses | Severity of disease
Study, Year | Setting | Major eligibility criteria (Percent of recruited patients excluded^*^) | | Patients' diagnoses
Study, Year | Setting | Major eligibility criteria (Percent of recruited patients excluded^*^) | Other invasive/noninvasive tests for CVD function | Patients' diagnoses | PAC | Control
PAC vs No PAC
Guyatt, 1991 (31) | M/SICU | Intensive care, medically sick, and postoperative and trauma who might benefit from PAC Exclude: Patients in whom the clinician felt that PAC was an ethical imperative (35%) or contraindicated (20%) [Other 22%] | On assisted ventilation with PEEP≥10 cm H_2_O, MBP<65 mm Hg or PO_2_ <60mmHg with CVP ≥10 cm H_2_O, urine output <0.5mL/Kg bw/hr in the presence of hypoxemia | Sepsis, MI, respiratory failure, trauma, perioperative, gastrointestinal bleeding or others | APACHE
Guyatt, 1991 (31) | M/SICU | | On assisted ventilation with PEEP≥10 cm H_2_O, MBP<65 mm Hg or PO_2_ <60mmHg with CVP ≥10 cm H_2_O, urine output <0.5mL/Kg bw/hr in the presence of hypoxemia | Sepsis, MI, respiratory failure, trauma, perioperative, gastrointestinal bleeding or others | 20 | 23
Guyatt, 1991 (31) | M/SICU | | | Sepsis, MI, respiratory failure, trauma, perioperative, gastrointestinal bleeding or others
Guyatt, 1991 (31) | M/SICU | | CVP | Sepsis, MI, respiratory failure, trauma, perioperative, gastrointestinal bleeding or others
Valentine, 1998 (7) | SICU | Elective abdominal aortic reconstruction Exclude: Kidney failure (2%) or additional vascular procedures needed (21%) | nd | AAA with normal cardiac status or fixed defects | nd
Valentine, 1998 (7) | SICU | Elective abdominal aortic reconstruction Exclude: Kidney failure (2%) or additional vascular procedures needed (21%) | | AAA with normal cardiac status or fixed defects | nd
Valentine, 1998 (7) | SICU | Elective abdominal aortic reconstruction Exclude: Kidney failure (2%) or additional vascular procedures needed (21%) | Adenosine thallium scintigraphy | AAA with normal cardiac status or fixed defects | nd
Bonazzi, 2002 (30) | SICU | Elective infrarenal abdominal aortic reconstruction, without clinical and echocardiographic evidence of CAD Exclude: High risk patients (nd) | Ejection fraction ≥ 50 | Infrarenal AAA | APACHE II
Bonazzi, 2002 (30) | SICU | Elective infrarenal abdominal aortic reconstruction, without clinical and echocardiographic evidence of CAD Exclude: High risk patients (nd) | Ejection fraction ≥ 50 | Infrarenal AAA | 7 | 7
Bonazzi, 2002 (30) | SICU | Elective infrarenal abdominal aortic reconstruction, without clinical and echocardiographic evidence of CAD Exclude: High risk patients (nd) | | Infrarenal AAA
Bonazzi, 2002 (30) | SICU | Elective infrarenal abdominal aortic reconstruction, without clinical and echocardiographic evidence of CAD Exclude: High risk patients (nd) | Transthoracic echocardiography | Infrarenal AAA
Berlauk, 1991 (29) | SICU | In situ vein graft bypass for limb salvage Exclude: Clinical settings for which literature supports the use of PAC, ie, unstable patients (nd) | PAC: 60% SVR>1000 dynes/sec cm^-5^, 13% CI<2.8 L/min/M^2^, 22% PAWP>15 mm Hg Control: Not done | Lower-extremity atherosclerotic arterial occlusive disease | nd
Berlauk, 1991 (29) | SICU | In situ vein graft bypass for limb salvage Exclude: Clinical settings for which literature supports the use of PAC, ie, unstable patients (nd) | | Lower-extremity atherosclerotic arterial occlusive disease | nd
Berlauk, 1991 (29) | SICU | In situ vein graft bypass for limb salvage Exclude: Clinical settings for which literature supports the use of PAC, ie, unstable patients (nd) | CVP | Lower-extremity atherosclerotic arterial occlusive disease | nd
Harvey, 2005 (32) | MICU | ICU admission, identified “as someone who should be managed with a PAC” Exclude: “Lack of equipoise from treating physician” (9%) [Other 11%] | nd | Acute respiratory failure, multiorgan dysfunction, decompensated heart failure | APACHE II
Harvey, 2005 (32) | MICU | ICU admission, identified “as someone who should be managed with a PAC” Exclude: “Lack of equipoise from treating physician” (9%) [Other 11%] | nd | Acute respiratory failure, multiorgan dysfunction, decompensated heart failure | 22 | 23
Harvey, 2005 (32) | MICU | ICU admission, identified “as someone who should be managed with a PAC” Exclude: “Lack of equipoise from treating physician” (9%) [Other 11%] | nd | Acute respiratory failure, multiorgan dysfunction, decompensated heart failure
Harvey, 2005 (32) | MICU | ICU admission, identified “as someone who should be managed with a PAC” Exclude: “Lack of equipoise from treating physician” (9%) [Other 11%] | nd | Acute respiratory failure, multiorgan dysfunction, decompensated heart failure | SOFA
Harvey, 2005 (32) | MICU | ICU admission, identified “as someone who should be managed with a PAC” Exclude: “Lack of equipoise from treating physician” (9%) [Other 11%] | nd | Acute respiratory failure, multiorgan dysfunction, decompensated heart failure | 9 | 9
Sandham, 2003 (37) | SICU | Major abdominal, thoracic, vascular, or orthopedic surgery; ASA class III or IV risk for surgery Exclude: None (†) | nd | CAD | ASA class III or IV risk Goldman index 8
Sandham, 2003 (37) | SICU | Major abdominal, thoracic, vascular, or orthopedic surgery; ASA class III or IV risk for surgery Exclude: None (†) | | CAD | ASA class III or IV risk Goldman index 8
Sandham, 2003 (37) | SICU | Major abdominal, thoracic, vascular, or orthopedic surgery; ASA class III or IV risk for surgery Exclude: None (†) | CVP | CAD | ASA class III or IV risk Goldman index 8
Richard, 2003 (36) | ICU (mixed units) | ICU admission with shock and/or ARDS Exclude: Shock for >12 hr or ARDS for <24 hr, hemorrhagic or some with cardiogenic shock, moribund (nd) | Respiratory rate ≥20/min, PaCO_2_ ≤32 mmHg, or acute decrease in PaO_2_/FIO_2_ to ≤200 mmHg | Shock and/or ARDS | SOFA
Richard, 2003 (36) | ICU (mixed units) | ICU admission with shock and/or ARDS Exclude: Shock for >12 hr or ARDS for <24 hr, hemorrhagic or some with cardiogenic shock, moribund (nd) | Respiratory rate ≥20/min, PaCO_2_ ≤32 mmHg, or acute decrease in PaO_2_/FIO_2_ to ≤200 mmHg | Shock and/or ARDS | 10 | 10
Richard, 2003 (36) | ICU (mixed units) | ICU admission with shock and/or ARDS Exclude: Shock for >12 hr or ARDS for <24 hr, hemorrhagic or some with cardiogenic shock, moribund (nd) | Respiratory rate ≥20/min, PaCO_2_ ≤32 mmHg, or acute decrease in PaO_2_/FIO_2_ to ≤200 mmHg | Shock and/or ARDS
Richard, 2003 (36) | ICU (mixed units) | ICU admission with shock and/or ARDS Exclude: Shock for >12 hr or ARDS for <24 hr, hemorrhagic or some with cardiogenic shock, moribund (nd) | Respiratory rate ≥20/min, PaCO_2_ ≤32 mmHg, or acute decrease in PaO_2_/FIO_2_ to ≤200 mmHg | Shock and/or ARDS | SAPS II
Richard, 2003 (36) | ICU (mixed units) | ICU admission with shock and/or ARDS Exclude: Shock for >12 hr or ARDS for <24 hr, hemorrhagic or some with cardiogenic shock, moribund (nd) | Respiratory rate ≥20/min, PaCO_2_ ≤32 mmHg, or acute decrease in PaO_2_/FIO_2_ to ≤200 mmHg | Shock and/or ARDS | 54 | 54
Richard, 2003 (36) | ICU (mixed units) | ICU admission with shock and/or ARDS Exclude: Shock for >12 hr or ARDS for <24 hr, hemorrhagic or some with cardiogenic shock, moribund (nd) | Respiratory rate ≥20/min, PaCO_2_ ≤32 mmHg, or acute decrease in PaO_2_/FIO_2_ to ≤200 mmHg | Shock and/or ARDS
Richard, 2003 (36) | ICU (mixed units) | ICU admission with shock and/or ARDS Exclude: Shock for >12 hr or ARDS for <24 hr, hemorrhagic or some with cardiogenic shock, moribund (nd) | Respiratory rate ≥20/min, PaCO_2_ ≤32 mmHg, or acute decrease in PaO_2_/FIO_2_ to ≤200 mmHg | Shock and/or ARDS | Odin
Richard, 2003 (36) | ICU (mixed units) | ICU admission with shock and/or ARDS Exclude: Shock for >12 hr or ARDS for <24 hr, hemorrhagic or some with cardiogenic shock, moribund (nd) | Respiratory rate ≥20/min, PaCO_2_ ≤32 mmHg, or acute decrease in PaO_2_/FIO_2_ to ≤200 mmHg | Shock and/or ARDS | 3.4 | 3.4
Richard, 2003 (36) | ICU (mixed units) | ICU admission with shock and/or ARDS Exclude: Shock for >12 hr or ARDS for <24 hr, hemorrhagic or some with cardiogenic shock, moribund (nd) | | Shock and/or ARDS
Richard, 2003 (36) | ICU (mixed units) | ICU admission with shock and/or ARDS Exclude: Shock for >12 hr or ARDS for <24 hr, hemorrhagic or some with cardiogenic shock, moribund (nd) | CVP, echocardiography | Shock and/or ARDS | Brussels
Richard, 2003 (36) | ICU (mixed units) | ICU admission with shock and/or ARDS Exclude: Shock for >12 hr or ARDS for <24 hr, hemorrhagic or some with cardiogenic shock, moribund (nd) | CVP, echocardiography | Shock and/or ARDS | 2.7 | 2.7
ESCAPE, 2005 (14) | CCU | Severe symptomatic heart failure Exclude: Kidney failure, use of inotropic drugs, crossover to PAC for urgent management unlikely based on recent medical history (nd) | PAC: LVEF=19%, SBP=106 mm Hg Control: LVEF=20%, SBP=106 mm Hg | Advanced heart failure | MLHF
ESCAPE, 2005 (14) | CCU | Severe symptomatic heart failure Exclude: Kidney failure, use of inotropic drugs, crossover to PAC for urgent management unlikely based on recent medical history (nd) | PAC: LVEF=19%, SBP=106 mm Hg Control: LVEF=20%, SBP=106 mm Hg | Advanced heart failure | 74 | 73
ESCAPE, 2005 (14) | CCU | Severe symptomatic heart failure Exclude: Kidney failure, use of inotropic drugs, crossover to PAC for urgent management unlikely based on recent medical history (nd) | | Advanced heart failure
ESCAPE, 2005 (14) | CCU | Severe symptomatic heart failure Exclude: Kidney failure, use of inotropic drugs, crossover to PAC for urgent management unlikely based on recent medical history (nd) | | Advanced heart failure
Rhodes, 2002 (35) | ICU | ICU admission, identified as requiring a PAC Exclude: Elective high-risk surgery requiring supranormalized circulation (nd); unethical to withhold PAC (0.5%) | PAC: PaO_2_/FIO_2_ (kPa)=25, MAP=79 mm Hg Control: PaO_2_/FIO_2_ (kPa)=23, MAP=78 mm Hg | Shock, multi-organ dysfunction, kidney failure, ARDS | APACHE II
Rhodes, 2002 (35) | ICU | ICU admission, identified as requiring a PAC Exclude: Elective high-risk surgery requiring supranormalized circulation (nd); unethical to withhold PAC (0.5%) | PAC: PaO_2_/FIO_2_ (kPa)=25, MAP=79 mm Hg Control: PaO_2_/FIO_2_ (kPa)=23, MAP=78 mm Hg | Shock, multi-organ dysfunction, kidney failure, ARDS | 22 | 19
Rhodes, 2002 (35) | ICU | ICU admission, identified as requiring a PAC Exclude: Elective high-risk surgery requiring supranormalized circulation (nd); unethical to withhold PAC (0.5%) | | Shock, multi-organ dysfunction, kidney failure, ARDS
Rhodes, 2002 (35) | ICU | ICU admission, identified as requiring a PAC Exclude: Elective high-risk surgery requiring supranormalized circulation (nd); unethical to withhold PAC (0.5%) | CVP | Shock, multi-organ dysfunction, kidney failure, ARDS | SOFA
Rhodes, 2002 (35) | ICU | ICU admission, identified as requiring a PAC Exclude: Elective high-risk surgery requiring supranormalized circulation (nd); unethical to withhold PAC (0.5%) | CVP | Shock, multi-organ dysfunction, kidney failure, ARDS | 7 | 7
PAC vs CVP
Isaacson, 1990 (33) | SICU | Abdominal aortic reconstructive Exclude: Inoperable, severe CAD or other condition where PAC monitoring would be mandatory (24%) [Other 23%] | LVEF >40% | Abdominal aortic diseases | ASA class III or IV risk
Isaacson, 1990 (33) | SICU | Abdominal aortic reconstructive Exclude: Inoperable, severe CAD or other condition where PAC monitoring would be mandatory (24%) [Other 23%] | | Abdominal aortic diseases | ASA class III or IV risk
Isaacson, 1990 (33) | SICU | Abdominal aortic reconstructive Exclude: Inoperable, severe CAD or other condition where PAC monitoring would be mandatory (24%) [Other 23%] | CVP | Abdominal aortic diseases | ASA class III or IV risk
Shoemaker, 1988; 1990 (39;41) | SICU | High risk of dying after surgery Exclude: Not ill enough to require intensive monitoring (12%) | nd | One or more of the high risk diseases including severe cardiorespiratory illness, extensive ablative surgery, multiple trauma, etc. | nd
Shoemaker, 1988; 1990 (39;41) | SICU | High risk of dying after surgery Exclude: Not ill enough to require intensive monitoring (12%) | | One or more of the high risk diseases including severe cardiorespiratory illness, extensive ablative surgery, multiple trauma, etc. | nd
Shoemaker, 1988; 1990 (39;41) | SICU | High risk of dying after surgery Exclude: Not ill enough to require intensive monitoring (12%) | CVP | One or more of the high risk diseases including severe cardiorespiratory illness, extensive ablative surgery, multiple trauma, etc. | nd
Wheeler, 2006 NHLBI (15) | ICU | Acute lung injury receiving ventilation, PaO_2_/FIO_2_<300, pulmonary edema but not due to left atrial hypertension Exclude:^‡^ Physician refusal (15%), presence of PAC (19%), severe medical conditions (52%) [Other 24%] | PAC: MAP=78 mm Hg, vasopressor use=36%, met shock criteria=37% Control: MAP=77 mmHg, vasopressor use=30%, met shock criteria=32% | Acute lung injury | APACHE III
Wheeler, 2006 NHLBI (15) | ICU | | PAC: MAP=78 mm Hg, vasopressor use=36%, met shock criteria=37% Control: MAP=77 mmHg, vasopressor use=30%, met shock criteria=32% | Acute lung injury | 95 | 94
Wheeler, 2006 NHLBI (15) | ICU | | | Acute lung injury
Wheeler, 2006 NHLBI (15) | ICU | | CVP | Acute lung injury
Bender, 1997 (5) | SICU | Infrarenal aortic reconstruction and/or lower limb revascularization Exclude: Recent severe cardiac disease (10%), proximal vascular cross-clamp (5%) | PAC: 8≤PAOP≤14 mm Hg, CI≥2.8 L/min/m^2^, SVR≤1100 dyne-sec/cm^2^ Control: nd | Aortic and non aortic vascular diseases with rest pain, ulcer, claudication, gangrene, aneurysm | nd
Bender, 1997 (5) | SICU | Infrarenal aortic reconstruction and/or lower limb revascularization Exclude: Recent severe cardiac disease (10%), proximal vascular cross-clamp (5%) | | Aortic and non aortic vascular diseases with rest pain, ulcer, claudication, gangrene, aneurysm | nd
Bender, 1997 (5) | SICU | Infrarenal aortic reconstruction and/or lower limb revascularization Exclude: Recent severe cardiac disease (10%), proximal vascular cross-clamp (5%) | Radial artery catheter | Aortic and non aortic vascular diseases with rest pain, ulcer, claudication, gangrene, aneurysm | nd
Schultz, 1985 (38) | ICU | Hip fracture, underprivileged, nutritionally depleted, poor physiologic condition Exclude: nd | PAC: RAP=3.6 mm Hg, PAWP=6.8 mm Hg | Hip fracture | nd
Schultz, 1985 (38) | ICU | Hip fracture, underprivileged, nutritionally depleted, poor physiologic condition Exclude: nd | | Hip fracture | nd
Schultz, 1985 (38) | ICU | Hip fracture, underprivileged, nutritionally depleted, poor physiologic condition Exclude: nd | CVP | Hip fracture | nd
Pearson, 1998 (34) | SICU | Elective cardiac surgical patients Exclude: nd N.B. Reassigned to PAC arm if PAC was indicated | PAC: LVEF=52% CVP: LVEF=64% | Elective cardiac surgery | nd
Pearson, 1998 (34) | SICU | Elective cardiac surgical patients Exclude: nd N.B. Reassigned to PAC arm if PAC was indicated | | Elective cardiac surgery | nd
Pearson, 1998 (34) | SICU | Elective cardiac surgical patients Exclude: nd N.B. Reassigned to PAC arm if PAC was indicated | CVP, Fiberoptic infrared mixed venous oxygen (SvO_2_) measuring PAC | Elective cardiac surgery | nd
Joyce, 1990 (40) | SICU | Elective infrarenal aortic reconstructive surgery; “low risk” only Exclude: unstable or poor cardiac function (nd) | PAC: LVEF>0.50, PAWP=9mmHg, CI=2.6L/min/m^2^, CVP=6, MAP=105 Control: CVP=8, MAP=86 | AAA | nd
Joyce, 1990 (40) | SICU | Elective infrarenal aortic reconstructive surgery; “low risk” only Exclude: unstable or poor cardiac function (nd) | | AAA | nd
Joyce, 1990 (40) | SICU | Elective infrarenal aortic reconstructive surgery; “low risk” only Exclude: unstable or poor cardiac function (nd) | Gated radionucleotide scan, CVP | AAA | nd

AAA, Abdominal aortic aneurysm; APACHE, Acute Physiology and Chronic Health Evaluation; ARDS, acute respiratory distress syndrome; ASA, American Society of Anesthesiologists; BP, blood pressure; bw, body weight; BSA, body surface area; CAD, coronary artery disease; CCU, cardiac care unit; CI, cardiac index; CRF, chronic renal failure; CVP, central venous pressure; DO_2_, oxygen delivery; FEV1, Forced expiratory volume in one second; FIO2, Fraction of inspired oxygen; ICU, intensive care unit; LV, left ventricular; LVEF, left ventricular ejection fraction; MAP, mean arterial pressure; MBP, mean blood pressure; MI, myocardial infarction; MICU, medical intensive care unit; M/SICU, medical/surgical intensive care unit; MLHF, Minnesota Living with Heart Failure questionnaire; nd, no data; PAC, pulmonary artery catheter; PaCO2, arterial partial pressure carbon dioxide; PaO2, arterial partial pressure oxygen; PAOP, pulmonary artery occlusion pressure; PAWP, pulmonary artery wedge pressure; PEEP, positive end expiratory pressure; RAP, Right atrial pressure; SAPS II, Simplified Acute Physiology score II; SBP, systolic blood pressure; SICU, surgical intensive care unit; SOFA, sepsis-related organ failure score; SVR, systemic vascular resistance.

* Percent of total number of potentially eligible patients who were excluded for the given reasons.

† All participating physicians agreed to refer all their eligible patients. Nevertheless, 28% of patients declined to participate, 10% had no bed available in the ICU, and 10% were not enrolled because their physicians failed to refer them to the study.

‡ Percentages extrapolated from appendix Table 1. Assumed that randomized patients were not included in percentages. Double counting of patients occurred because “one of several [exclusion] reasons” data used.

None of the studies established a specific protocol for how data from PAC (or CVP) were acted on; although the Shoemaker study stated that the therapeutic goals in the protocol group required sufficient quantities of fluids and inotropic agents to attain the therapeutic goals (39;41) and Wheeler 2006 had goals for maintaining blood pressure, urine output, and effective circulation based in part on PAC or CVP readings (15). Most studies did not report any information on how PAC data were handled or how treatment management was affected by the PAC data. In fact, among the studies that described treatments or protocols, most explicitly stated that no protocol was established and/or that clinical management was at the discretion of the treating clinicians. Four studies reported on the effect of PAC on use of treatments. Two studies found greater use of inotropic agents (Sandham 2003 (37), Wheeler 2006 (15)); but only Sandham 2003 reported greater use vasodilators, antihypertensive medications, packed red blood cells, and colloid. Pearson 1989 (34) reported no significant difference in duration of vasopressor administration and Wheeler 2006 reported no difference in use of fluids and diuretics (15). Harvey 2005 found that the most frequently reported changes in management due to PAC were fluid infusion, introduction and change in dose of vasoactive drugs (32).

Most studies included a majority of patients who were age 65 years or older, as judged by study mean or median ages. The overall (unadjusted) average age across studies was approximately 62 years. No study specifically included or excluded patients based on older age (65 years or older). Three studies included relatively young patients (compared to most studies), with mean ages less than 60 years (Wheeler 2006 (15), ESCAPE 2005 (14), Shoemaker 1988 (39)), while two had relatively older patients with mean ages over 70 years (Sandham 2003 (37), Schultz 1985 (38)). The different ages are likely due to the clinical heterogeneity related to various eligibility criteria and settings. No study evaluated whether outcomes differed based on patient ages. Across outcomes, there were no clear differences in outcomes based on the average age of patients.

Among the 9 studies that reported information about crossover (e.g., assignment to the control or CVP group, but received PAC regardless), the rate of crossovers was less than 2 percent in 4 studies (5;15;35;37) and up to 10 percent in 3 studies (14;32;36). In the Guyatt 1991 trial, 8 of 17 patients (47 percent) randomized to the control group had PAC at some point during their hospital stay because of “their deteriorating status;” 7 of these patients died. In the Pearson 1989 trial, 47 of 74 patients (64 percent) initially randomized to CVP were rerandomized to additional groups who received PAC (34). The high crossover rates in these studies calls into question the validity of the comparison. However, as these problematic studies are small there inclusion or exclusion from the metaanalyses do not substantially alter the summary results. With the goal of best approximating intention-to-treat analyses, where patients are analyzed in the arm to which they were assigned, regardless of ultimate treatment, we have included all studies in metaanalyses regardless of crossover rates. It should be noted though that high crossover rates tend to push results toward the null (finding no statistically significant difference between interventions).

Metaanalyses were performed for several clinical outcomes, where data permitted. Studies in all metaanalyses were grouped by type of comparisons (PAC vs. “no PAC”; PAC vs. CVP). Subgroup analyses on the two types of comparisons were performed. An overall effect estimate combining all studies in both groups was also calculated for each metaanalysis. Studies in each group of comparison were sorted by the study setting in the following order: cardiac or critical care unit (CCU), medical intensive care unit (MICU), intensive care unit (ICU), medical or surgical intensive care unit (M/SICU), and surgical intensive care unit (SICU). Although the study setting may be a source of heterogeneity, the number of available studies in all metaanalyses was too small to perform subgroup analyses based on study settings.

### Mortality

(Figure 1, Table 3)

Figure 1 Metaanalysis of odds ratio of death, PAC vs. control

* Rhodes 2002 reported only an adjusted OR of death. Exclusion of this study does not affect summary estimates.

Random effects model metaanalyses of odds ratio (OR) of death comparing patients who received PAC monitoring to patients who did not receive PAC monitoring in critical care settings. Diamonds display metaanalysis results centered on pooled estimates and extending to 95% confidence interval (CI). Squares and lines indicate OR estimates and 95% CI for individual studies. The size of the boxes are proportional to the weight of each study in the overall metaanalysis. Studies are ordered by setting, then sample size.

Appl, applicability rated W (wide), M (moderate), N (narrow); CCU, coronary care unit; CI confidence interval; Ctrl, control; CVP, central venous pressure catheter; ICU, intensive care unit; MICU, medical intensive care unit; n, number of events (death); N, number of patients; OR, odds ratio; PAC, pulmonary artery catheter; Quality, methodological quality rated A (good), B (fair), C (poor); SICU, surgical intensive care unit.

Figure 1 displays a forest plot of studies reporting the odds ratio of death, pulmonary artery catheter versus control. Data for Figure 1 are presented in Appendix E, Table 1. This figure is described further the section “Mortality” as follows: The overall odds ratio of death was 1.03 (95% CI 0.9, 1.2) comparing patients who received PAC monitoring to control patients who did not receive PAC monitoring in critical care settings. There was no statistically significant heterogeneity across the 15 studies. In the nine studies comparing PAC to no PAC monitoring, the random effects combined odds ratio of death was 1.03 (95% CI 0.9, 1.2). In the five studies comparing PAC to CVP monitoring, the random effects combined odds ratio of death was 0.96 (95% CI 0.5, 2.0). There was no statistically significant heterogeneity within each subgroup, and there was no statistically significant difference between the combined ORs in the two subgroups.

Table 3 Mortality in patients with PAC vs control in randomized controlled trials

Study, Year | Setting | No. Analyzed | | Mean Age (yr)^a^ | % Male a | Outcome | Metric/Units | Results | | | Quality | Applicability
Study, Year | Setting | PAC | Control | Mean Age (yr)^a^ | % Male a | Outcome | Metric/Units | Results | | | Quality | Applicability
Study, Year | Setting | PAC | Control | Mean Age (yr)^a^ | % Male a | Outcome | Metric/Units | PAC | Control | P Between | Quality | Applicability
PAC vs No PAC
Guyatt, 1991 (31) | M/SICU | 16 | 17 | 61 | 63 | All-cause | Net difference % | -10 | | NS | C | Moderate
Valentine, 1998 (7) | SICU | 60 | 58 | 64 | 100 | All-cause | % | 5 | 2 | NS | B | Narrow
Bonazzi, 2002 (30) | SICU | 50 | 50 | 67 | 100 | All-cause | % | 0 | 0 | NS | B | Narrow
Berlauk, 1991 (29) | SICU | 45^b^ | 21 | 68 | 49 | All-cause | % | 2.2 | 9.5 | 0.08 d | | Narrow
Berlauk, 1991 (29) | SICU | 23^c^ | 21 | 62 | 70 | All-cause | % | 0 | 9.5 | 0.08 d | | Narrow
Harvey, 2005 (32) | MICU | 506 | 507 | 65 | 57 | Hospital | Adj HR | 1.09 | | NS | A | Wide
Harvey, 2005 (32) | MICU | 506 | 507 | 65 | 57 | ICU | % | 60 | 57 | NS | A | Wide
Harvey, 2005 (32) | MICU | 506 | 507 | 65 | 57 | 28 day | % | 62 | 60 | NS | A | Wide
Sandham, 2003 (37) | SICU | 997 | 997 | 72 | 70 | Hospital | % | 7.8 | 7.7 | NS | A | Moderate
Sandham, 2003 (37) | SICU | 930 | 963 | 72 | 70 | 6 month | % | 12.6 | 11.9 | NS | A | Moderate
Sandham, 2003 (37) | SICU | 910 | 941 | 72 | 70 | 12 month | % | 17.9 | 16 | NS | A | Moderate
Sandham, 2003 (37) | SICU | 910 | 941 | 72 | 70 | 12 month | Adj RR | 1.0 | | NS | A | Moderate
Richard, 2003 (36) | ICU (mixed units) | 338 | 343 | 63 | 67 | 28 day | % | 59 | 61 | NS | A | Moderate
Richard, 2003 (36) | ICU (mixed units) | 338 | 343 | 63 | 67 | 28 day | Adj HR | 0.97 | | NS | A | Moderate
Richard, 2003 (36) | ICU (mixed units) | 338 | 343 | 63 | 67 | 28 day | 14 day RR | 0.97 | | NS | A | Moderate
Richard, 2003 (36) | ICU (mixed units) | 335 | 341 | 63 | 67 | 28 day | 90 day RR | 0.98 | | NS | A | Moderate
ESCAPE, 2005 (14) | CCU | 206 | 207 | 56 | 74 | ∼30 day | OR | 0.97 | | NS | A | Moderate
ESCAPE, 2005 (14) | CCU | 206 | 207 | 56 | 74 | 180 day | OR | 0.97 | | NS | A | Moderate
ESCAPE, 2005 (14) | CCU | 206 | 207 | 56 | 74 | 180 day | OR | 1.26 | | NS | A | Moderate
Rhodes, 2002 (35) | ICU | 96 | 105 | 68 Median | nd | 28 day | Adj OR | 0.96 | | NS | A | Wide
PAC vs CVP
Isaacson, 1990 (33) | SICU | 49 | 53 | 65 | nd | All-cause | No. | 1 | 0 | NS | B | Narrow
Shoemaker, 1988; 1990 (39;41) | SICU | 28^e^ | 30 | 56 | 75 | All-cause | % | 4 | 23 | <0.1 | B | Narrow
Shoemaker, 1988; 1990 (39;41) | SICU | 28^e^ | 30 | 53 | 75 | All-cause | % | 4 | 23 | <0.1 | B | Narrow
Shoemaker, 1988; 1990 (39;41) | SICU | 28^e^ | 30 | 53 | 39 | All-cause | % | 4 | 23 | <0.1 | B | Narrow
Shoemaker, 1988; 1990 (39;41) | SICU | 28^e^ | 30 | 53 | 39 | All-cause | % | 33 | 23 | NS | B | Narrow
Shoemaker, 1988; 1990 (39;41) | SICU | 30^f^ | 30 | 53 | 39 | All-cause | % | 33 | 23 | NS | B | Narrow
Wheeler, 2006 NHLBI (15) | ICU | 513 | 487 | 49 | 45 | 60 day | % | 27.4 | 26.3 | NS | A | Narrow
Wheeler, 2006 NHLBI (15) | ICU | 513 | 487 | 49 | 45 | 60 day | RR | 1.1 | | NS | A | Narrow
Bender, 1997 (5) | SICU | 51 | 53 | 65 | 63 | All-cause | No. | 1 | 1 | NS | B | Narrow
Schultz, 1985 (38) | ICU | 35 | 35 | 78 | 28 | All-cause | % | 2.9 | 29 | <0.01 | C | Narrow

a Values for the PAC group

b Group 1: PAC placement 12 hours before surgery

c Group 2: PAC placement 3 hours before surgery

d 2 PAC arms vs Control

e PAC-Protocol: Supranormal therapeutic goals

f PAC-Control: Similar therapeutic goals for CVP and PAC groups

A total of 15 trials reported data on death in patients received PAC monitoring and in the control patients in critical care settings (5;7;8;14;15;29-39). Of these, nine compared the mortality outcome of patients received PAC monitoring with those who received no PAC monitoring (7;14;29-32;35-37) and six compared PAC to patients received CVP monitoring (5;15;33;34;38;39). One study was in a CCU setting, one was in a MICU setting, four were in ICU settings, one was in a M/SICU setting, and eight were in SICU settings. Six studies each were of good or moderate methodological quality (Grade A or B, respectively) and three studies were of poor quality (Grade C). Two had wide applicability, 6 moderate applicability, 7 narrow applicability.

The overall odds ratio of death was 1.03 (95% CI 0.9, 1.2) comparing patients who received PAC monitoring to control patients who did not receive PAC monitoring in critical care settings. There was no statistically significant heterogeneity across the 15 studies. In the nine studies comparing PAC to no PAC monitoring, the random effects combined odds ratio of death was 1.03 (95% CI 0.9, 1.2). In the five studies comparing PAC to CVP monitoring, the random effects combined odds ratio of death was 0.96 (95% CI 0.5, 2.0). There was no statistically significant heterogeneity within each subgroup, and there was no statistically significant difference between the combined ORs in the two subgroups (Figure 1). Rhodes 2002, in contrast to the other trials, reported only an adjusted OR of death. Excluding this study from the analysis did not alter the summary estimates.

Schultz 1985 reported the greatest, and only statistically significant, benefit with PAC (38). This study was the first randomized trial that compared the outcomes of PAC monitoring to that of CVP monitoring in 70 generally older (mean age 72, range 40-95 years), underprivileged and nutritionally depleted hip fracture patients with poor physiologic condition. The trial showed a “highly significant” reduction in the mortality rate associated with the PAC monitoring (2.9% vs. 29%, P < 0.01). It was rated poor methodological quality (Grade C). The study provided no clear explanation for why such a large difference in mortality rates was found and no definitive explanation was found why this study differed from later trials. It is possible that, as has been found in other fields, this result occurred by chance and because of the large effect, in the absence of previous trials, was more likely to be published than if no benefit were found (42).

Two studies reported subgroup analyses of mortality. Sandham 2003 in a trial of almost 2000 patients undergoing high risk surgical procedures compared multiple subgroups (37). They found no evidence of variation of effect according to center (hospital), American Society of Anesthesiologists (ASA) risk class, type of surgery, sex, age, or New York Heart Association (NYHA) cardiac function class. Richard 2003 in a trial of almost 700 patients with shock or acute respiratory distress syndrome also found no difference in effect across subgroups based on diagnosis or the Simplified Acute Physiology Score II (36). However, neither study was powered to detect differences in mortality among subgroups, so the failure to find statistically significant differences does not rule out the possibility of real differences among subgroups.

### Length of Stay

(Figures 2 & 3, Tables 4 & 5)

Figure 2 Metaanalyses of mean difference in hospital length of stay (LOS), PAC vs. control

Random effects model metaanalyses of mean difference in hospital length of stay comparing patients who received PAC monitoring to patients who did not receive PAC monitoring in critical care settings. Diamonds display metaanalysis results centered on pooled estimates and extending to 95% confidence interval (CI). Squares and lines indicate estimates of means and 95% CI for individual studies. The size of the boxes are proportional to the weight of each study in the overall metaanalysis. Studies are ordered by setting, then sample size.

Appl, applicability rated W (wide), M (moderate), N (narrow); CCU, coronary care unit; CI confidence interval; Ctrl, control; CVP, central venous pressure catheter; d, days; ICU, intensive care unit; LOS, length of stay; MICU, medical intensive care unit; PAC, pulmonary artery catheter; Quality, methodological quality rated A (good), B (fair), C (poor); SICU, surgical intensive care unit.

Figure 2 displays a forest plot of studies reporting the mean difference in hospital length of stay, pulmonary artery catheter versus control. Data for Figure 2 are presented in Appendix E, Table 2. This figure is described further the section “Length of Hospital Stay” as follows: The overall mean difference in the length of hospital stays was 0.30 (95% CI -0.40, 0.99) days between patients who received PAC monitoring and control patients who did not receive PAC monitoring in critical care settings. There was no statistically significant heterogeneity across the 10 studies. In the seven studies that compared PAC to no PAC monitoring, the random effects combined mean difference in the length of hospital stay was 0.24 (95% CI -0.50, 0.97) days. In the three studies that compared PAC to CVP monitoring, the random effects combined mean difference in the length of hospital stay was 0.84 (95% CI -1.41, 0.99) days. There was no statistically significant heterogeneity within each subgroup, and there was no statistically significant difference between the combined risk differences in the two groups.

Figure 3 Metaanalyses of mean difference in ICU length of stay, PAC vs. control

Random effects model metaanalyses of mean difference in intensive care unit (ICU) length of stay comparing patients who received PAC monitoring to patients who did not receive PAC monitoring in critical care settings. Diamonds display metaanalysis results centered on pooled estimates and extending to 95% confidence interval (CI). Squares and lines indicate estimates of means and 95% CI for individual studies. The size of the boxes are proportional to the weight of each study in the overall metaanalysis. Studies are ordered by setting, then sample size.

CI confidence interval; Ctrl, control; CVP, central venous pressure catheter; d, days; ICU, intensive care unit; LOS, length of stay; PAC, pulmonary artery catheter.

Figure 3 displays a forest plot of studies reporting the mean difference in intensive care unit length of stay, pulmonary artery catheter versus control. Data for Figure 3 are presented in Appendix E, Table 3. This figure is described further the section “Length of ICU Stay” as follows: The overall mean difference in the length of hospital stay was 0.00 (95% CI -0.45, 0.46) days between patients who received PAC monitoring and control patients who did not receive PAC monitoring in critical care settings. There was no statistically significant heterogeneity across the eight studies. In the four studies that compared PAC to no PAC monitoring, the random effects combined mean difference in the length of hospital stay was 0.33 (95% CI -0.56, 1.22) days. In the four studies that compared PAC to CVP monitoring, the random effects combined mean difference in the length of hospital stay was 0.07 (95%CI -0.70, 0.55) days. There was no statistically significant heterogeneity within each subgroup, and there was no statistically significant difference between the combined risk differences in the two groups.

Table 4 Length of hospital stay in patients with PAC vs control in randomized controlled trials

Study, Year | Setting | No. Analyzed | | Mean Age (yr)^a^ | % Male a | Sample | Metric/Units | Results | | | Quality | Applicability
Study, Year | Setting | PAC | No PAC | Mean Age (yr)^a^ | % Male a | Sample | Metric/Units | PAC | No PAC | P between | Quality | Applicability
PAC vs No PAC
Harvey, 2005 (32) | MICU | 506 | 508 | 65 | 57 | Survivors | days, median | 34 | 40 | NS | A | Wide
Harvey, 2005 (32) | MICU | 506 | 508 | 65 | 57 | Non survivors | days, median | 3 | 3 | NS | A | Wide
Rhodes, 2002 (35) | ICU | 96 | 105 | 68 | nd | All | days, median | 13 | 14 | NS | A | Wide
Rhodes, 2002 (35) | ICU | 96 | 105 | median | nd | Survivors | days, median | 29 | 25 | NS | A | Wide
Sandham, 2003 (37) | SICU | 997 | 997 | 72 | 70 | Hospital | days, median | 10 | 10 | NS | A | Moderate
ESCAPE, 2005 (14) | CCU | 206 | 207 | 56 | 74 | All | HR | 1.04 | | NS | A | Moderate
Guyatt, 1991 (31) | MICU, | 16 | 17 | 61 | 63 | All | Net difference, days | -2.2 | | NS | C | Moderate
Guyatt, 1991 (31) | SICU | 16 | 17 | 61 | 63 | All | Net difference, days | -2.2 | | NS | C | Moderate
Valentine, 1998 (7) | SICU | 60 | 58 | 64 | 100 | All | days | 13 | 13 | NS | B | Narrow
Berlauk, 1991 (29) | SICU | 45^b^ | 21 | 68 | 49 | All | days | 19.4 | 15.4 | NS | B | Narrow
Berlauk, 1991 (29) | SICU | 23^c^ | 21 | 62 | 70 | | | 18.0 | 15.4 | NS | B | Narrow
Bonazzi, 2002 (30) | SICU | 50 | 50 | 67 | 100 | All | days | 12 | 11 | NS | B | Narrow
PAC vs CVP
Isaacson, 1990 (33) | SICU | 49 | 53 | 65 | nd | All | days | 10.2 | 9.4 | NS | B | Narrow
Shoemaker, 1988; 1990 (39;41) | SICU | 28 d | 30 | 56 | 75 | All | days | 19.3 | 22.2 | NS | B | Narrow
Shoemaker, 1988; 1990 (39;41) | SICU | 30^e^ | 30 | 53 | 39 | All | days | 25.2 | 22.2 | NS | B | Narrow
Bender, 1997 (5) | SICU | 51 | 53 | 65 | 63 | All | days | 12.5 | 12.0 | NS | B | Narrow

CCU, coronary care unit; ICU, intensive care unit; HR, hazard ratio; MICU, medical intensive care unit; nd, no data; NS, non-significant; PAC, pulmonary artery catheter; SICU, surgical intensive care unit; vs, versus; yr, year; %, percentage

a Values for the PAC group

b Group 1: PAC placement 12 hours before surgery

c Group 2: PAC placement 3 hours before surgery

d PAC-Protocol: Supranormal therapeutic goals

e PAC-Control: Similar therapeutic goals for CVP and PAC groups

Table 5 Length of intensive care unit (ICU) stay in patients with PAC vs control in randomized controlled trials

Study, Year | Setting | No. Analyzed | | Mean Age (yr)^a^ | % Male a | Sample | Metric/Units | Results | | P Between | Quality | Applicability
Study, Year | Setting | PAC | Control | Mean Age (yr)^a^ | % Male a | Sample | Metric/Units | PAC | Control | P Between | Quality | Applicability
PAC vs No PAC
Harvey, 2005 (32) | MICU | 506 | 508 | 65 | 57 | Survivors | days, median | 12.1 | 11.0 | NS | A | Wide
Harvey, 2005 (32) | MICU | 506 | 508 | 65 | 57 | Non survivors | days, median | 2.6 | 2.5 | NS | A | Wide
Rhodes, 2002 (35) | ICU | 96 | 105 | 68 median | nd | All | days, median | 5.7 | 4 | NS | A | Wide
Rhodes, 2002 (35) | ICU | 96 | 105 | 68 median | nd | Survivors | days, median | 10 | 6 | NS | A | Wide
Valentine, 1998 (7) | SICU | 60 | 58 | 64 | 100 | All | days | 8 | 7 | NS | B | Narrow
Berlauk, 1991 (29) | SICU | 45^b^ | 21 | 68 | 49 | All | days | 3.5 | 2.6 | NS | B | Narrow
Berlauk, 1991 (29) | SICU | 23^c^ | 21 | 62 | 70 | All | days | 2.5 | 2.6 | NS | B | Narrow
PAC vs CVP
Wheeler 2006 (15) | ICU | 513 | 487 | 49 | 45 | All | ICU-free day, at day 28 | 12.0 | 12.5 | NS | A | Narrow
Isaacson, 1990 (33) | SICU | 49 | 53 | 65 | nd | All | days | 2.1 | 2.7 | NS | B | Narrow
Shoemaker, 1988; 1990 (39;41) | SICU | 28^d^ | 30 | 56 | 75 | All | days | 10.2 | 11.5 | NS | B | Narrow
Shoemaker, 1988; 1990 (39;41) | SICU | 30^e^ | 30 | 53 | 39 | All | days | 15.8 | 11.5 | NS | B | Narrow
Bender, 1997 (5) | SICU | 51 | 53 | 65 | 63 | All | days | 2.7 | 2.6 | NS | B | Narrow
Pearson, 1998 (34) | SICU | 86 | 26 | nd | nd | All | days | 1.6 | 1.35 | NS | C | Moderate
Pearson, 1998 (34) | SICU | 33^f^ | 26 | nd | nd | All | days | 2.8 | 1.35 | NS | C | Moderate

ICU, intensive care unit; MICU, medical intensive care unit; nd, no data; NS, non-significant; PAC, pulmonary artery catheter; SICU, surgical intensive care unit; vs, versus; yr, year; %, percentage.

a Values for the PAC group

b Group 1: PAC placement 12 hours before surgery

c Group 2: PAC placement 3 hours before surgery

d PAC-Protocol: Supranormal therapeutic goals

e PAC-Control: Similar therapeutic goals for CVP and PAC groups

f Reassigned to PAC group

A total of 13 trials reported data on the length of hospital stay and/or on the length of ICU stay (5;7;14;15;29-31;33-37;39). Of these, Rhodes 2002 uniquely reported the median length of hospital and ICU stay and their confidence intervals were expressed as percent changes (35). Therefore, it was excluded in the metaanalyses of length of hospital or ICU stay. However, consistent with the other trials, Rhodes 2002 did not find any statistically significant difference in the length of hospital or ICU stay between patients received PAC monitoring and those who received no PAC monitoring (CVP allowed).

#### Length of Hospital Stay

(Figure 2, Table 4)

Ten trials reported data on the length of hospital stay in patients received PAC monitoring and in the control patients in critical care settings (5;7;14;29-31;33;36;37;39). Of these, seven compared length of hospital stay in patients who received PAC monitoring with those who received no PAC monitoring (7;14;29-31;36;37) and three compared that with patients who received CVP monitoring (5;33;39). One study was in a CCU setting, one was in an ICU setting, one was in a M/SICU setting, and seven were in SICU settings. Three and seven studies were of good or moderate methodological quality (Grade A or B), respectively. Four studies were of moderate applicability, 6 narrow.

The mean lengths of hospital stay ranged from 9 to 25 days in the PAC monitoring groups and from 8 to 22 days in the control groups. The overall mean difference in the length of hospital stays was 0.30 (95% CI -0.40, 0.99) days between patients who received PAC monitoring and control patients who did not receive PAC monitoring in critical care settings. There was no statistically significant heterogeneity across the 10 studies. In the seven studies that compared PAC to no PAC monitoring, the random effects combined mean difference in the length of hospital stay was 0.24 (95% CI -0.50, 0.97) days. In the three studies that compared PAC to CVP monitoring, the random effects combined mean difference in the length of hospital stay was 0.84 (95% CI -1.41, 0.99) days. There was no statistically significant heterogeneity within each subgroup, and there was no statistically significant difference between the combined risk differences in the two groups (Figure 2).

#### Length of ICU Stay

(Figure 3, Table 5)

A total of eight trials reported data on the length of ICU stay in patients who received PAC monitoring and in the control patients in critical care settings (5;7;15;29;33;34;36;39). Of these, three compared length of ICU stay in patients receiving PAC monitoring with those receiving no PAC monitoring (7;29;36) and five compared that to patients who received CVP monitoring (5;15;33;34;39). Two studies were in ICU settings and six were in the SICU settings. One and six studies were of good or moderate methodological quality (Grade A or B), respectively, and one was of poor quality (Grade C). Two were of moderate applicability, 6 narrow.

The mean lengths of ICU stay ranged from 2 to 16 days in the PAC monitoring groups and from 1 to 16 days in the control groups. The overall mean difference in the length of hospital stay was 0.00 (95% CI -0.45, 0.46) days between patients who received PAC monitoring and control patients who did not receive PAC monitoring in critical care settings. There was no statistically significant heterogeneity across the eight studies. In the four studies that compared PAC to no PAC monitoring, the random effects combined mean difference in the length of hospital stay was 0.33 (95% CI -0.56, 1.22) days. In the four studies that compared PAC to CVP monitoring, the random effects combined mean difference in the length of hospital stay was -0.07 (95%CI -0.70, 0.55) days. There was no statistically significant heterogeneity within each subgroup, and there was no statistically significant difference between the combined risk differences in the two groups. (Figure 3)

### Medical morbidities

(Tables 6 & 7)

Table 6 Reports of medical morbidities (overall, cardiovascular, and pulmonary events) in randomized trials

See Tables 11, 12, and 15 for cardiovascular and pulmonary complications attributable to PAC.

Study | N | | Overall | | | | Cardiovascular | | | | Pulmonary
Study
Study | PAC | Control | Outcome | PAC | Control | P | Outcome | PAC | Control | P | Outcome | PAC | Control | P
Sandham ( 37 ) | 997 | 997 | | | | | Myocardial infarction | 4% | 3% | NS
Sandham ( 37 ) | 997 | 997 | | | | | CHF | 13% | 11% | NS
Wheeler NHLBI ( 15 ) | 513 | 487
ESCAPE ( 14 ) | 215 | 218 | ≥1 event a | 21.9% | 11.5% | .04 | Cardiogenic shock | 0.5% | 0.9% | NS
ESCAPE ( 14 ) | 215 | 218 | ≥1 event b | 20% | 11.5% | nd | Ischemia/angina | 4.2% | 1.8% | NS
ESCAPE ( 14 ) | 215 | 218 | | | | | Myocardial infarction | 0% | 0.5% | NS
ESCAPE ( 14 ) | 215 | 218 | | | | | Stroke/TIA | 0.5% | 0% | NS
ESCAPE ( 14 ) | 215 | 218 | | | | | Cardiac arrest | 4.2% | 2.3% | NS
Rhodes ( 35 ) | 96 | 105 | | | | | | | | | ARDS | ≥14% c | ≥17% c | NS
Berlauk ( 29 ) | 66 | 21 | All | 17% | 43% | nd | Overall | 11% | 24% | nd | Overall | 0% | 0%
Berlauk ( 29 ) | 66 | 21 | All | 17% | 43% | nd | CHF | 6% | 5% | nd
Berlauk ( 29 ) | 66 | 21 | All | 17% | 43% | nd | Myocardial infarction | 5% | 14% | nd
Valentine ( 7 ) | 60 | 60 | Post-operative | 25% | 17% | NS | Overall | 15% | 7% | NS | Overall | 12% | 9% | NS
Valentine ( 7 ) | 60 | 60 | Post-operative | 25% | 17% | NS | Stroke | 0% | 0% | | Overall
Shoemaker (39;41) | 58 | 30 | Organ failure | 55% | 73% | nd | Myocardial infarction | 3% | 0% | nd | Respiratory failure | 17% | 23% | nd
Shoemaker (39;41) | 58 | 30 | Overall | 0.9/pt | 1.0/pt | nd | Pulmonary edema | 9% | 0% | nd | Pulmonary effusion | 10% | 7% | nd
Bender ( 5 ) | 51 | 53 | All | 14% | 13% | nd | Myocardial infarction | 6% | 9% | nd
Bender ( 5 ) | 51 | 53 | All | 14% | 13% | nd | Pulmonary edema | 4% | 2% | nd
Bonazzi ( 30 ) | 50 | 50 | | | | | Overall | 4% | 4% | NS
Isaacson ( 33 ) | 49 | 53 | | | | | Myocardial infarction / cardiogenic shock | 2% | 2% | nd | Pulmonary effusion | 2% | 2% | nd
Isaacson ( 33 ) | 49 | 53 | | | | | Pulmonary edema | 2% | 2% | nd | Pulmonary effusion | 2% | 2% | nd
Joyce ( 40 ) | 21 | 19 | | | | | Overall | 0 | 0

Percentages in bold were “substantially” larger than other arm (though generally nonsignificantly so).

ARDS, acute respiratory distress syndrome; CHF, congestive heart failure; nd, no data; NS, statistically nonsignificant; PAC, pulmonary artery catheter; pt, (events per) patient; TIA, transient ischemic attack.

a including PAC infection (4 v 0 events)

b without PAC infection (assuming no other events occurred in these patients)

c Number (and %) of patients with outcomes reported and statistical analyses on a daily basis for 0-5 days. These values represent the maximum percentage of patients on any given day. It is possible that a larger percentage of patients had the condition at some time during the 5 days. The statistical analyses are only for daily rates.

Table 11 Incidence of clinically significant arrhythmias in patients with PAC (or control, in parentheses)

See Table 6 for data from RCTs on other, non-PAC-attributed cardiovascular outcomes.

Author | Year | Adverse Event | Setting | No. Analyzed | Mean Age (yr) | Male (%) | % with Adverse Event | Quality | Applicability
Shah (57) | 1984 | Persistent PVCs requiring treatment | nd | 6245 | 62 | nd | 3.1 | C | Moderate
Damen (54) | 1986 | Ventricular fibrillation | Cardiac ICU | 1305 | nd | nd | 3 | B | Narrow
Wheeler (15) | 2006 | Ventricular arrhythmia | ICU | 513 | 49 | 45 | 3.7 | A | Narrow
Harvey (32) | 2005 | Arrhythmia requiring treatment | Medical ICU | 486 | 65 | 57 | 3 | A | Wide
Rhodes (35) | 2002 | Dysrhythmia, severe | General ICU | 96 | 68 | nd | 3 | A | Wide
Wheeler (15) | 2006 | Conduction defect | ICU | 513 | 49 | 45 | 1.0 | A | Narrow
Shah (57) | 1984 | LBBB resulting in complete heart block | nd | 6245 [113 a] | 62 | nd | 0.02 [0.9% a] | C | Moderate
Lopez-Sendon (56) | 1990 | Ventricular tachycardia | Coronary care unit | 2821 | 60 | 83 | 0.04 | B | Narrow
Damen (54) | 1986 | Ventricular tachycardia | Cardiac ICU | 1305 | nd | nd | 0.2 | B | Narrow
Sandham (37) | 2003 | Ventricular tachycardia | Surgical ICU | 941 (965) | 72 | 70 | 0.2 (0.2) NS | A | Moderate
Boyd (53) | 1983 | Ventricular tachycardia | All | 500 | nd | nd | 1.5 | B | Narrow
ESCAPE (14) investigators | 2005 | Ventricular tachycardia | Cardiac ICU | 215 | 46 | 74 | 0.5 | A | Moderate
Total | | Ventricular tachycardia | | 5782 | | | 0.2% b

ICU, intensive care unit; LBBB, left bundle branch block; nd, no data; PAC, pulmonary artery catheter; PVC, premature ventricular contractions.

a Patients with pre-existing LBBB

b Simple pooled (averaged) estimate. I.e., weighted only by sample size. All summary percentages are likely to be overestimates since studies without events that did not explicitly report no events are not included.

Table 12 Incidence of hemothorax and pneumothorax in patients with PAC (or control, in parentheses)

See Table 6 for data from RCTs on other, non-PAC-attributed pulmonary outcomes.

Author | Year | Adverse Event | Setting | No. Analyzed | Mean Age (yr) | Male (%) | % with Adverse Event | Quality | Applicability
Sandham (37) | 2003 | Hemothorax | Surgical ICU | 941 (965) | 72 | 70 | 0.2 (0) NS | A | Moderate
Wheeler (15) | 2006 | Hemothorax | ICU | 513 | 49 | 45 | 0.6 | A | Narrow
Harvey (32) | 2005 | Hemothorax | Medical ICU | 486 | 65 | 57 | 0.2 | A | Wide
Richard (36) | 2003 | Hemothorax | ICU (mixed units) | 342 | 62 | 67 | 0.3 | B | Moderate
Total | | Hemothorax | | 2282 | | | 0.3% a
Shah (57) | 1984 | Pneumothorax | nd | 6245 | 62 | nd | 0.5 | C | Moderate
Damen (54) | 1986 | Pneumothorax | Cardiac ICU | 1305 | nd | nd | 0.1 | B | Narrow
Sandham (37) | 2003 | Pneumothorax | Surgical ICU | 941 (965) | 72 | 70 | 0.9 (0.4) NS | A | Moderate
Wheeler (15) | 2006 | Pneumothorax | ICU | 513 | 49 | 45 | 1.2 | A | Narrow
Harvey (32) | 2005 | Pneumothorax | Medical ICU | 486 | 65 | 57 | 0 | A | Wide
Rhodes (35) | 2002 | Pneumothorax | General ICU | 96 (105) | 68 | nd | 0 (0) | A | Wide
Berlauk (29) | 1991 | Pneumothorax | Surgical ICU | 68 (21) | 66 | 56 | 1.5 (0) NS | B | Narrow
Valentine (7) | 1998 | Pneumothorax | Surgical ICU | 60 | 64 | 100 | 2 | B | Narrow
Total | | Pneumothorax | | 9714 | | | 0.5% a

ICU, intensive care unit; nd, no data; PAC, pulmonary artery catheter.

a Simple pooled (averaged) estimate. I.e., weighted only by sample size. All summary percentages are likely to be overestimates since studies without events that did not explicitly report no events are not included.

Table 15 Incidence of embolism related events in patients with PAC (or control, in parentheses)

See Table 6 for data from RCTs on other, non-PAC-attributed pulmonary outcomes.

Author | Year | Adverse Event | Setting | No. Analyzed | Mean Age (yr) | Male (%) | % with Adverse Event | Quality | Applicability
Wheeler (15) | 2006 | Air embolism | ICU | 513 | 49 | 45 | 0.6 | A | Narrow
Sandham (37) | 2003 | Pulmonary embolism | Surgical ICU | 941 (965) | 72 | 70 | 0.9 (0) P=.004 | A | Moderate
Wheeler (15) | 2006 | Pulmonary embolism or deep vein thrombosis | ICU | 513 | 49 | 45 | 0 | A | Narrow
Boyd (53) | 1983 | Pulmonary embolism | All | 500 | nd | nd | 0.4 | B | Narrow
Richard (36) | 2003 | Pulmonary embolism | ICU (mixed units) | 342 | 62 | 67 | 0 | B | Moderate
Total | | Pulmonary embolism | | 2296 | | | 0.5% a
Sandham (37) | 2003 | Pulmonary infarction | Surgical ICU | 941 (965) | 72 | 70 | 0.1 (0) NS | A | Moderate

ICU, intensive care unit; nd, no data; PAC, pulmonary artery catheter.

a Simple pooled (averaged) estimate. I.e., weighted only by sample size. All summary percentages are likely to be overestimates since studies without events that did not explicitly report no events are not included.

Table 7 Reports of medical morbidities (renal, infection, hepatic, graft thrombosis, and gastrointestinal events) in randomized trials

See Table 14 for infectious complications attributable to PAC

Study | N | | Renal | | | | Infection | | | | Other
Study | PAC | Control | Outcome | PAC | Control | P | Outcome | PAC | Control | P | Outcome | PAC | Control | P
Sandham ( 37 ) | 997 | 997 | Renal insufficiency | 7.4% | 9.8% | .07 | Pneumonia | 6.7% | 7.3% | NS | Hepatic insufficiency | 2.4% | 2.7% | NS
Wheeler NHLBI ( 15 ) | 513 | 487 | Renal replacement | 14% | 11% | NS
ESCAPE ( 14 ) | 215 | 218 | SCr | worsen with ed less PAC | | nd | Infection | 13% | 9% | NS
Rhodes ( 35 ) | 96 | 105 | Renal failure | ≥35% a | ≥21% a | NS a
Berlauk ( 29 ) | 66 | 21 | Renal failure | 2% | 5% | nd | | | | | Graft thrombosis | 3% | 19% | nd
Valentine ( 7 ) | 60 | 60 | Overall | 7% | 2% | NS | | | | | Graft thrombosis | 0% | 0%
Shoemaker (39;41) | 58 | 30 | Renal failure | 12% | 23% | nd | Sepsis | 16% | 20% | nd | Hepatic failure | 3% | 7% | nd
Bender ( 5 ) | 51 | 53 | | | | | Sepsis | 4% | 4% | | Graft thrombosis | 2% | 2% | nd
Bonazzi ( 30 ) | 50 | 50 | Renal failure | 0 | 0
Isaacson ( 33 ) | 49 | 53 | Renal injury | 4% | 2% | nd | | | | | Gastro-intestinal | 2% | 2% | nd
Joyce ( 40 ) | 21 | 19 | Renal failure | 0 | 0

Percentages in bold were “substantially” larger than other arm (though generally nonsignificantly so). nd, no data; NS, statistically nonsignificant; PAC, pulmonary artery catheter; SCr, serum creatinine.

a Number (and %) of patients with outcomes reported and statistical analyses on a daily basis for 0-5 days. These values represent the maximum percentage of patients on any given day. It is possible that a larger percentage of patients had the condition at some time during the 5 days. The statistical analyses are only for daily rates.

Eleven trials reported comparative rates of various medical morbidities between patients with PAC and either no PAC or CVP (5;7;14;15;29;30;33;35;37;39-41). The medical morbidities included “overall,” cardiovascular, pulmonary, renal, infection, hepatic, graft thrombosis, and gastrointestinal, but do not include adverse events related to PAC use. Across studies and morbidities, only the ESCAPE trial reported a statistically significant difference in morbidity event rates, such that at least one morbidity occurred in about twice as many patients who had PAC than who did not have PAC (14). In all the studies, where event rates differed, the number of events that occurred more commonly without PAC was equal to the number of events that were more common with PAC. The total rates of any event reported among patients with and without PAC were roughly equal such that in both groups, overall, about 1 event was reported per 3 patients investigated.

#### Overall

(Table 6)

Five studies reported some variation of total number of medical morbidities. As noted, only the ESCAPE trial found a significant difference based on intervention, favoring no PAC. Valentine 1998 also found a somewhat higher rate of postoperative medical morbidity in those with PAC. In contrast, Berlauk 1991 and Shoemaker 1988/1990 found substantially higher medical morbidity rates in those who did not receive PAC. Shoemaker1988/1990 was actually designed to compare an active protocol based on PAC with both a CVP control and a PAC control (without the active protocol). While similar rates of events occurred in the PAC and PAC “control” arms, the 28 patients in the PAC protocol arm had only one organ failure (respiratory), a significantly lower rate of events than the controls. The final study, Bender 1997, found equal rates of events.

#### Cardiovascular

(Table 6)

Nine trials reported rates of cardiovascular events. None reported statistically significant differences in rates of various events, including myocardial infarction, congestive heart failure, pulmonary edema, cardiogenic shock, cardiac arrest, stroke, and overall cardiac events. There was no consistent finding of either patients with or without PAC having fewer cardiovascular events.

#### Pulmonary

(Table 6)

Among the five studies that reported pulmonary events, three found no substantial differences in event rates and the two others came had opposite findings about whether specific respiratory events were more common with or without PAC. The pulmonary morbidities reported were respiratory failure, pulmonary effusion, acute respiratory distress syndrome, and overall pulmonary events.

#### Renal

(Table 7)

Ten studies reported on kidney injury, including need for renal replacement therapy. The studies were evenly distributed among those that found higher rates of renal events with or without PAC, or that found no difference in rates.

#### Infectious disease

(Table 7)

Only clinically significant infections likely related to the patients' underlying medical or surgical diseases are included here. Studies that reported only infections that were deemed to be related to PAC are discussed under Question 4 on adverse events related to PAC. Studies that reported wound infections, bacteremia (alone), or other relatively minor infections were not included.

Four studies reported rates of either pneumonia, sepsis or septic shock, or general infection. The ESCAPE trial did not define what was meant by “infection,” except that these did not include PAC-related infections; but this trial was included nonetheless. Consistent with their findings for other medical morbidities, ESCAPE found somewhat higher rates of infection with PAC, Shoemaker 1988/1990 found a somewhat higher rate of sepsis without PAC, and the other two trials found similar rates of either pneumonia or sepsis, regardless of PAC.

#### Miscellaneous medical morbidities

(Table 7)

Other clinically important medical morbidities that were evaluated were hepatic insufficiency or failure, gastrointestinal events, and graft thrombosis (after peripheral vascular disease surgery). These were evaluated by six studies. No consistent relative event rates were found across studies.

### Duration of ventilation

(Table 8)

Table 8 Duration of ventilation in patients with PAC vs control in randomized controlled trials

Study, Year | Setting | No. Analyzed | | Mean Age (yr) a | % Male a | Outcome | Results | | | | Quality | Applicability
Study, Year | Setting | PAC | Control | Mean Age (yr) a | % Male a | Outcome | Metric/Units | PAC | Control | P Between | Quality | Applicability
PAC vs No PAC
Valentine, 1998 (7) | SICU | 60 | 58 | 64 | 100 | Ventilation | hours | 35 | 6 | NS | B | Narrow
PAC vs CVP
Wheeler 2006 (15) | ICU | 513 | 487 | 49 | 45 | Ventilator-free days, day 28 | days | 13.2 | 13.5 | NS | A | Narrow
Shoemaker, 1988; 1990 (39;41) | SICU | 28 b | 30 | | 75 | Duration of ventilation | days | 2.3 | 4.6 | NS | B | Narrow
Shoemaker, 1988; 1990 (39;41) | SICU | 30 c | 30 | 53 | 39 | Duration of ventilation | days | 9.4 | 4.6 | NS | B | Narrow

ICU, intensive care unit; MICU, medical intensive care unit; nd, no data; No., number; NS, non-significant; PAC, pulmonary artery catheter; SICU, surgical intensive care unit; SOFA, vs, versus; yr, year; %, percentage.

a Values for the PAC group

b PAC-Protocol: Supranormal therapeutic goals

c PAC-Control: Similar therapeutic goals for CVP and PAC groups

Three trials reported on differences in duration of mechanical ventilation in patients with either PAC or CVP monitoring (7;15;39;41). All three trials found no statistically significant difference in mean duration of time that patients required mechanical ventilation. A relatively large trial of 1000 patients in the ICU (Wheeler 2006) found similar numbers of ventilator-free days. Two smaller surgical ICU-based trials of 58 patients (Shoemaker 1988/1990) and 118 patients (Valentine 1998) found no significant differences in time on ventilation. Valentine did find a much greater duration of ventilation in those with PAC, but the variance of the duration of ventilation among the PAC group was so large that our estimated 95% confidence interval for the difference between the two arms is −2 hours (favoring no PAC) to +72 hours.

### Quality of life and disease severity scores

(Table 9)

Table 9 Quality of life or symptom score in patients with PAC vs control in randomized controlled trials

Study, Year | QOL/ symptom | Setting | No. Analyzed | | Mean Age (yr) a | % Male a | Baseline Score^1^ | Metric / Units (Score Range) | Results | | | Quality | Applicability
Study, Year | QOL/ symptom | Setting | PAC | No PAC | Mean Age (yr) a | % Male a | Baseline Score^1^ | Metric / Units (Score Range) | PAC | No PAC | P Between | Quality | Applicability
PAC vs No PAC
Bonazzi, 2002 (30) | SOFA 2^nd^ postop. day | SICU | 50 | 50 | 67 | 100 | 10 b | Score (24 max, lower=better) | 8 | 8 | NS | B | Narrow
ESCAPE, 2005 (14) | Symptom score (global) | CCU | 215 | 208 | 56 | 74 | 43 | Score (?100 max, implied higher=better) | +25 | +24 | NS | A | Moderate
ESCAPE, 2005 (14) | Minnesota Living with Heart Failure questionnaire | CCU | 215 | 208 | 56 | 74 | nd | nd | PAC better than No PAC at 1 month, but not 6 months | | | A | Moderate
ESCAPE, 2005 (14) | Orthopnea score | CCU | 215 | 208 | 56 | 74 | 3.3 | Score (0-4) | -1.4 | -1.2 | NS | A | Moderate
Guyatt, 1991 (31) | Lowest modified APACHE | MICU, SICU | 16 | 17 | 61 | 63 | | Final Score, adjusted for baseline | 10.8 | 7.0 | .03 (favoring No PAC) | B | Moderate
Guyatt, 1991 (31) | Mean modified APACHE | MICU, SICU | 16 | 17 | 61 | 63 | | Final Score, adjusted for baseline | 14.4 | 11.1 | .04 (favoring No PAC) | B | Moderate
Rhodes, 2002 (35) | SOFA scores, 0-5 d change | ICU | 96 | 105 | 68 median | nd | 7 median | Score (24 max, lower=better) | -3 | -4 | NS | A | Wide

APACHE, Acute Physiology And Chronic Health Evaluation; CCU, cardiac care unit; ICU, intensive care unit; MICU, medical intensive care unit; nd, no data; No., number; NS, non-significant; PAC, pulmonary artery catheter; SICU, surgical intensive care unit; SOFA, Systemic Organ Failure Assessment; vs, versus; yr, year; %, percentage.

a Values for the PAC group

b 6 hours after surgery

Four trials evaluated different measures of quality of life (or disease severity). In total, the studies compared 377 patients who had PAC used and 380 without PAC (14;30;31;35). Two were deemed to be of good quality and two fair quality. The trials varied in applicability from narrow to wide and each study evaluated patients in different settings.

The ESCAPE trial reported that the Minnesota Living with Heart Failure questionnaire improved in both groups by 1 month, with greater improvement in the PAC group, but that by 6 months the control group matched the PAC group. No further data were reported. They found no differences in changes in either a global symptom score or an orthopnea score (both of which improved equally in both groups of patients).

In a relatively small study of only 33 randomized patients, Guyatt 1991 found that changes in (baseline-adjusted) modified APACHE scores were statistically significantly worse after PAC use than without PAC at discharge from the intensive care unit. However, the two studies that evaluated the Systemic Organ Failure Assessment (SOFA) score found no differences between interventions.

### Optimization of treatment

No study that met eligibility criteria reported data on maximization of ACE inhibitor dose or other types of treatment optimization.

## Question 4 What complications and adverse events associated with pulmonary artery catheter monitoring have been reported?

### Summary of review articles on PAC complications

To complement the systematic review of PAC complications among RCTs and larger cohort studies, we collected information from various more comprehensive reviews (both systematic and narrative) of PAC complications. The review articles commonly divide complications temporally according to the (a) insertion, (b) management, and (c) removal of the PACs. A list of reported complications associated with each period is shown in Table 10.

Table 10 Complications associated with pulmonary artery catheters

Insertion | Maintenance | Removal
Pneumothorax | Infection | Hemorrhage
Hemothorax / hemomediastinum | Bacteremia | Air embolism
Hematoma / hemorrhage | Candidemia | Arrhythmia
Accidental arterial puncture | Sepsis | Cardiovascular damage
Arrhythmia | Local infection | Vascular
Anaphylaxis (latex allergy) | Lung abscess / empyema | Valvular
Cardiovascular damage | Endocarditis | Cardiac wall
Vascular | Embolism | Catheter shear
Valvular | Air
Cardiac wall | Thrombus
Air embolism | Catheter / balloon
Guide wire loss or fragmentation | Pulmonary infarct
| Arrhythmia
| Hemorrhage
| Vascular / cardiac rupture / damage
| Vessel thrombosis

#### Complications associated with PAC insertion

Kelso et al. performed a systematic review of articles that primarily described complications associated with PAC use from 1979 to 1996 (43). A variety of complications, including most events listed in Table 10, are discussed. However, evidence on event rates were described only for a few outcomes. Most studies were retrospective in design and many included relatively few individuals. No attempts at metaanalysis were performed. The best estimate of cardiac arrhythmias requiring treatment was ≤3 percent (44). It was noted that complete heart block was rare, most commonly occurring in patients with left bundle branch block, potentially fatal, but the incidence is unknown.

In an issue-length review of complications of invasive hemodynamic monitoring in the intensive care unit from 1988, Sladen describes and provides opinions on a wide range of complications, but includes only occasional estimates of event rates. Among those highlighted are risks of pneumothorax (1.4 percent) and arterial puncture (7.7 percent) during central venous access (45). Both of these estimates are from a 1986 report of 142 patients (46).

None of the reviews discussed loss of the guidewire into patient during insertion, though this is one of the primary complications taught to medical personnel during training. This complication may have been the cause of several of the described complications including cardiac arrhythmias, major artery and vein rupture, pulmonary embolism, pneumothorax, and thrombosis.

#### Complications associated with PAC maintenance

The most commonly described complications described that occur while the PAC is being left in place and used for hemodynamic monitoring are infections, pulmonary artery and right ventricular damage, and pulmonary infarction. Kelso et al. reported several estimates of rates of infections including bacteremia in 1-6 percent of patients and local infections in 19 percent (43). In an extensive review of infectious complications of PACs from 1994, Mermel and Maki (47) describe infectious endocarditis occurring in less than 2 percent of patients (by autopsy). Other infectious complications described include septic thrombosis (infected thrombus surrounding the catheter), septic pulmonary emboli, bacteremia, candidemia, pulmonary artery mycotic aneurysm, parenchymal lung abscess and empyema. However, they note that while many prospective studies of risk have been published, few used unambiguous criteria for catheter-related bloodstream infections and several of these were small or did not report complete analyses. From 14 prospective studies with at least 75 catheters, reported between 1979 and approximately 1993, it was estimated that 0-4.6 percent of catheters produce bacteremia or candidemia (median 1.0 percent) and there were 0-13.2 (median 4.8) cases of bacteremia or candidemia per 1000 catheter-days. They note though that these reports “May underestimate the true incidence of PAC-related bloodstream infection because it is not clear in most of the reported studies whether a proactive effort was made by the investigators to assure that blood cultures were done in every patient with fever or other signs of sepsis” (47).

Kelso et al. report a range of rates of pulmonary artery rupture or aneurysm from 0.03-0.2 percent, with mortality of 45-65 percent across various studies (43). Liu and Webb, in introductory material for their analysis of reported PAC-related deaths, note pulmonary artery rupture rates between 0.016 and 1.0 percent, with a mortality rate above 50 percent (48). Kelso et al. also give a series of rare events described in case reports and series, including right ventricle perforation, air embolism, thrombosis formation, catheter fragment embolization, and pulmonary infarct.

Notably, they categorize “inappropriate treatment of a patient based upon inaccurate hemodynamic measurements” as a complication. They note two studies of practitioner knowledge of PAC (49;50). Among almost 500 North American physicians, the mean multiple-choice test score was 67 percent correct (49). A slightly revised version of the test was given to two groups of American nurses who scored about 50 percent correct (50).

#### Complications associated with PAC removal

The adverse events that have been described to occur at PAC removal include catheter knotting, arrhythmias, catheter shear (tearing), and structural damage. These have been reported in case reports (43). Karanikas et al. report on a systematic review of case reports of catheter knotting (51). They found reports of 53 PAC catheter knots between 1950 and 2000 (they also report on knots in other catheters). Almost 60 percent were successfully removed using interventional radiological techniques, but one-third required surgery. Four catheter knots were left in situ. However six of the reported cases (8 percent) died as a direct result of the catheter knot.

#### Death

Liu and Webb (48) performed an analysis of the manufacturer and user facility device experience database gathered by the Food and Drug Administration (FDA). Between 1993 and 1999 48 deaths associated with PAC were reported to the FDA. Of these, 42 (88 percent) were due to pulmonary artery rupture, 2 were due to air embolism, 1 each were due to pleural cavity perforation and cardiac tamponade, and 2 were due to other causes. However, no estimate of a denominator or the reporting rate were made.

### Systematic review of PAC complications

Eighteen studies met our eligibility criteria for review of PAC complications (5;7;14;15;29;30;32;35-37;39;40;52-57). These included 12 of the randomized trials eligible for Key Question 3 (with a total of 3,017 patients who received PAC), 3 prospective cohort studies with at least 500 patients with PAC (6,986 patients total), and 3 retrospective analyses with at least 500 patients with PAC (39,187 patients total).

With the possible exception of the adverse events reported in the retrospective study of 32,442 patients (55), the event rates we summarized are likely to be high estimates of the true rates. This is so because for each adverse event we have included only those studies that explicitly report rates of the adverse event. We did not assume that lack of reporting meant that no adverse events (including death) occurred. Though relatively common adverse events may have been omitted by some authors, we consider it more likely that adverse events that were rare or did not occur in a particular sample of patients were more likely to be omitted.

From the RCTs, we attempted to extract equivalent adverse event data from both the PAC and the control arms under the assumption that some of the PAC-attributed “complications” (eg, ventricular arrhythmia, sepsis) may not in fact have been related to PAC placement or may have equally occurred due to CVP or other line placement. However, this approach was limited because no study reported the number of relevant events specifically in patients who had CVPs and many comparative studies reported these events only among patients with PAC. Nevertheless, three RCTs reported complication data. These data are presented in Tables 11-15, along with statistical significance of relative event rates.

Table 13 Incidence of major bleeding events in patients with PAC (or control, in parentheses)

Author | Year | Adverse Event | Setting | No. Analyzed | Mean Age (yr) | Male (%) | % with Adverse Event | Quality | Applicability
Sandham (37) | 2003 | Arterial puncture | Surgical ICU | 941 (965) | 72 | 70 | 0.3 (0.1) NS | A | Moderate
Wheeler (15) | 2006 | Arterial puncture | ICU | 513 | 49 | 45 | 0.6 | A | Narrow
Shah (57) | 1984 | Carotid artery puncture | nd | 6245 | 62 | nd | 1.9 | C | Moderate
Damen (54) | 1986 | Carotid artery puncture | Cardiac ICU | 1305 | nd | nd | 4.8 | B | Narrow
Boyd (53) | 1983 | Carotid artery puncture | All | 500 | nd | nd | 1.5 | B | Narrow
Harvey (32) | 2005 | Carotid artery puncture | Medical ICU | 486 | 65 | 57 | 3 | A | Wide
Total | | Carotid artery puncture | | 8536 | | | 2.4% a
Kearney (55) | 1995 | Pulmonary artery rupture | OR & ICU | 32442 | nd | nd | 0.03 | C | Narrow
Bossert (52) | 2006 | Pulmonary artery rupture | Surgical ICU | 2860 | nd | nd | 0.07 | C | Narrow
Total | | Pulmonary artery rupture | | 35302 | | | 0.03% a
Shah (57) | 1984 | Pulmonary hemorrhage | nd | 6245 | 62 | nd | 0.06 | C | Moderate
Sandham (37) | 2003 | Pulmonary hemorrhage | Surgical ICU | 941 (965) | 72 | 70 | 0.3 (0) NS | A | Moderate
Boyd (53) | 1983 | Pulmonary hemorrhage | All | 500 | nd | nd | 0.2 | B | Narrow
ESCAPE (14) investigators | 2005 | Pulmonary infarction / hemorrhage | Cardiac ICU | 215 | 56 | 74 | 0.9 | A | Moderate
Total | | Pulmonary hemorrhage | | 7901 | | | 0.1% a

ICU, intensive care unit; OR, operating room; nd, no data; PAC, pulmonary artery catheter.

a Simple pooled (averaged) estimate. I.e., weighted only by sample size. All summary percentages are likely to be overestimates since studies without events that did not explicitly report no events are not included.

Table 14 Incidence of clinically significant infections related complications in patients with PAC (or control, in parentheses)

See Table 7 for data from RCTs on other, non-PAC-attributed infections.

Author | Year | Adverse Event | Setting | No. Analyzed | Mean Age (yr) | Male (%) | % with Adverse Event | Quality | Applicability
Boyd (53) | 1983 | Endocarditis | All | 500 | nd | nd | 0 | B | Narrow
ESCAPE (14) investigators | 2005 | “PAC-related infection” | Cardiac ICU | 215 | 56 | 74 | 1.9 | A | Moderate
Wheeler (15) | 2006 | Septicemia & other infections a | ICU | 513 | 49 | 45 | 1.0 | A | Narrow
Sandham (37) | 2003 | Sepsis | Surgical ICU | 941 (965) | 72 | 70 | 1.3 (1.3) NS | A | Moderate
Wheeler (15) | 2006 | Septicemia | ICU | 513 | 49 | 45 | 1.0 | A | Narrow
Boyd (53) | 1983 | Septicemia | All | 500 | nd | nd | 1.3 | B | Narrow
Richard (36) | 2003 | Septicemia | ICU (mixed units) | 342 | 62 | 67 | 3 | B | Moderate
Valentine (7) | 1998 | Sepsis | Surgical ICU | 60 | 64 | 100 | 3 | B | Narrow
Total | | Sepsis | | 2356 | | | 1.6% b

ICU, intensive care unit; nd, no data; PAC, pulmonary artery catheter.

a Not including “local” infections

b Simple pooled (averaged) estimate. I.e., weighted only by sample size. All summary percentages are likely to be overestimates since studies without events that did not explicitly report no events are not included.

#### Arrhythmia

(Table 11)

Nine studies with 13,122 patients reported event rates of various clinically significant arrhythmias (not including transient arrhythmias not requiring treatment). Five studies with 8645 patients reported on different potentially severe arrhythmias, or those requiring treatment, each finding event rates of approximately 3 percent. Ventricular tachycardia was explicitly reported by five studies of 5782 patients (one of which also reported on severe arrhythmias) and found in approximately 0.2 percent across studies; although a wide range, from 0.04 to 1.5 percent among the studies, possibly suggesting that different definitions of ventricular tachycardia were used or that the underlying risk of the event differed in the different study populations with different medical and surgical conditions. Notably, the rate of ventricular tachycardia was the same in the one RCT that reported rates in both arms (PAC and standard of care, where CVP was allowed) (37).

#### Pneumothorax and hemothorax

(Table 12)

Eight studies with 9714 patients reported rates of pneumothorax related to PAC use; three of these studies and a fourth study also reported on hemothorax rates in 2282 patients with PAC. Among these studies pneumothorax rates varied between 0 and 2 percent and hemothorax rates between 0.2 and 0.6 percent. Overall, about 1 in 200 patients evaluated experienced a pneumothorax and 1 in 325 patients a hemothorax related to PAC use. If we assume that no pneumothoraces or hemothoraces occurred in studies that reported only one of the events, then the overall rate of pneumothoraces remains the same at about 1 in 200 (0.5 percent), but drops to about 1 in 1500 (0.07 percent) for hemothoraces. Notably, the rates of hemothorax and pneumothorax were lower or the same in three RCTs (29;35;37).

#### Major bleeding events

(Table 13)

Nine studies with 45,507 patients reported rates of major artery punctures and pulmonary hemorrhage, though 32,442 patients were from one retrospective analysis of patients receiving PACs either in the operating room or the intensive care unit. Carotid artery punctures were relatively common, occurring in approximately 2.4 percent of patients in four studies (range 1.5 to 4.8 percent). Pulmonary artery rupture was reported by the large retrospective study, for which this was the primary outcome of interest, and relatively large prospective study. The two studies found broadly similar rates of 0.03 and 0.07 percent, respectively. Among four studies with 7901 patients, pulmonary hemorrhage (or infarction) occurred in approximately 1 in 800 patients, overall (range 0.06 and 0.9 percent). In one RCT, the rate of arterial punctures and of pulmonary hemorrhage was similar in both arms (37).

#### Infections

(Table 14)

Six studies with 2571 patients receiving PAC reported on clinically significant infections related to PAC use. We did not include reports of superficial or other wound infections that required only topical care. We attempted to exclude reports of positive blood cultures that either were not reported to have any clinical impact or that cleared with PAC removal. It is likely though that we misclassified the clinical importance of the septic events that were reported by the various studies. Among the five studies that appeared to be reporting on clinically important septicemia, this outcome occurred in approximately 1.6 percent of 2356 patients. Notably, though, among the larger studies (500 or more patients) about 1 percent of patients had septicemia, while the rate was 3 percent in each of the smaller studies. The rate of sepsis was the same in the one RCT that reported rates in both the PAC and usual care (some with CVP) arms (37). Two studies reported either that 1 percent of patients had septicemia or other infections (not including local infections) and that 2 percent had “PAC related infections.” One study of 500 patients reported no cases of endocarditis. This outcome was not reported by other studies.

#### Embolism

(Table 15)

Four studies with 2296 patients reported rates of pulmonary embolism. Across studies about 0.5 percent of patients suffered a pulmonary embolism; though rates in the individual studies ranged from 0 to almost 1 percent. One of these studies reported that 1 patient among 941 who received PAC had a pulmonary infarction. A separate study reported that among 513 patients, 2 patients (0.6 percent) had air embolisms. Sandham 2003 found statistically significantly more pulmonary emboli among patients who had PACs (8/941, 0.9 percent) than who had standard care, some of whom had CVPs (0/965, P=0.004) (37). The rates of pulmonary infarctions, though were equivalently low.

#### Catheter knotting

(Table 16)

Table 16 Incidence of catheter knotting at PAC removal

Author | Year | Adverse Event | Setting | No. Analyzed | Mean Age (yr) | Male (%) | % with Adverse Event | Quality | Applicability
Bossert (52) | 2006 | Catheter knotting | Surgical ICU | 2860 | nd | nd | 0.03 | C | Narrow
Richard (36) | 2003 | Catheter knotting | ICU (mixed units) | 342 | 62 | 67 | 1.8 | B | Moderate
ESCAPE (14) investigators | 2005 | Catheter knotting | Cardiac ICU | 215 | 46 | 74 | 0.9 | A | Moderate
Total | | Catheter knotting | | 3417 | | | 0.3% a

ICU, intensive care unit; nd, no data; PAC, pulmonary artery catheter.

a Simple pooled (averaged) estimate. I.e., weighted only by sample size. All summary percentages are likely to be overestimates since studies without events that did not explicitly report no events are not included.

Three studies reported rates of catheter knotting. The large prospective cohort study of 2860 patients in surgical intensive care units found a very low rate of 0.03 percent (1 patient), while the two smaller randomized trials found rates of about 1 to 2 percent (8 patients among 557 patients total). The reason for the discrepancy is unclear; although it is possible that different definitions of knotting were used, possibly including simple catheter looping within the right ventricle. Alternatively, poorer technique may have been used in the randomized trials in medical units than the cohort in surgical units, or that the event was underreported in the surgical units.

#### Death

(Table 17)

Table 17 Incidence of death directly connected with PAC

Author | Year | Adverse Event | Setting | No. Analyzed | Mean Age (yr) | Male (%) | % with Adverse Event | Quality | Applicability
Shah (57) | 1984 | Death (uncontrolled hemorrhage) | nd | 6245 | 62 | nd | 0.02 | C | Moderate
Wheeler (15) | 2006 | Death (due to PAC) | ICU | 513 | 49 | 45 | 0 | A | Narrow
Boyd (53) | 1983 | Death (due to PAC) | All | 500 | nd | nd | 0 | B | Narrow
ESCAPE (14) investigators | 2005 | Death (related to PAC) | Cardiac ICU | 215 | 56 | 74 | 0 | A | Moderate
Shoemaker (39) | 1988 | Death (or other major event) | Surgical ICU | 174 | 54 | 62 | 0 | B | Narrow
Bender (5) | 1997 | Death (or other major event) | Surgical ICU | 51 | 65 | 63 | 0 | B | Narrow
Bonazzi (30) | 2002 | Death (or other major event) | Surgical ICU | 50 | 67 | 100 | 0 | B | Narrow
Joyce (40) | 1990 | Death (or other major event) | Surgical ICU | 21 | 68 | 68 | 0 | B | Narrow
Total | | Death | | 7769 | | | 0.01% a

ICU, intensive care unit; nd, no data; PAC, pulmonary artery catheter.

a Simple pooled (averaged) estimate. I.e., weighted only by sample size. All summary percentages are likely to be overestimates since studies without events that did not explicitly report no events are not included.

Among nine studies with 7769 patients, only 1 death (0.01 percent) related to PAC use was reported. The death occurred in the largest study (a retrospective cohort). The death was due to accidental overinflation of the balloon while measuring PAOP which resulted in massive pulmonary hemorrhage. If it can be assumed that no other deaths related to PAC occurred in the other studies that reported adverse events (omitting the evaluation of pulmonary rupture (55) in 32,422 patients) then the PAC-death rate was 1 in 16,748 or 0.006 percent.