# Methods

This report on the benefits and harms of pulmonary artery catheter (PAC) use in critical care settings is based both on a systematic review of the literature and on narrative reviews. For the background information on PACs, we used a narrative review approach to describe the devices and techniques that are currently used to assess cardiac output and volume status in critical care settings, and the indications for PAC placement (Questions 1 & 2). For questions regarding the effect of and adverse events associated with PAC, we performed systematic reviews.

The approach, methodology, and criteria used were agreed upon by consensus of the Evidence-based Practice Center (EPC) clinician-methodologists, an expert in cardiology and intensive care based at Tufts Medical Center, Centers for Medicare & Medicaid Services (CMS) staff organizing a Medicaid Coverage Advisory Committee (MCAC) meeting on PAC, and staff at the Agency for Healthcare Research and Quality (AHRQ) with methodological expertise.

## Search Strategy

A comprehensive search of the scientific literature was conducted to identify relevant studies addressing the key questions. In September 2006 we searched MEDLINE® (from 1966 to present), MEDLINE® In-Process & Other Non-Indexed Citations, and Cochrane databases (3rd quarter 2006) English language studies of adult humans to identify articles relevant to each key question. We also reviewed reference lists of related systematic reviews and selected narrative reviews and primary articles. In electronic searches, we used various terms for pulmonary artery catheters (including Swan-Ganz), limited to adult humans, and relevant research designs (see Appendix A for complete search strategy). We did not systematically search for unpublished data.

## Study Selection

We assessed titles and/or abstracts of citations identified from literature searches for inclusion, using the criteria described below. Full-text articles of potentially relevant abstracts were retrieved and a second review for inclusion was conducted by reapplying the inclusion criteria. A low threshold was used to retrieve articles for full rescreening. Results published only in abstract form are not included in our reviews because adequate information is not available to assess the validity of the data and these reports have generally not been peer-reviewed.

### Population and condition of interest

We included studies of adults (≥ 18 years old) with conditions requiring inpatient hemodynamic monitoring. Conditions included but were not limited to heart failure, preoperative evaluation with compromised left ventricular function (for cardiac or noncardiac surgery), dialysis (to assess volume status), acute respiratory distress syndrome, and related pulmonary conditions. We excluded studies of preheart transplant patients for whom evaluation with PAC is a standard method for assessing transplant status, and the pregnancy-related population including postpartum women, a population considered to have limited applicability to the Medicare population in the intensive care setting.

### Interventions of interest

The intervention of interest was PAC used for “treatment management”, as either intermittent or continual measurement devices. This description of the intervention of interest is purposely broad to avoid excluding potentially relevant studies. It includes studies where PAC was used to assist with the management of patients after initial diagnoses are made. Studies of PACs that were used only for the purpose of initial diagnosis (e.g., type of shock or cause of hypotension) or that were used for single-reading measurements (e.g. “in and out”) were excluded.

### Comparators of interest

The acceptable comparators of interest included other noninvasive and less invasive techniques for the management of cardiac output and volume status. We also included studies that used “no PAC” as a comparator. We excluded studies that used experimental devices (where PAC is the reference standard).

### Outcomes of interest

We analyzed clinical outcomes of greatest interest to CMS, in discussion with our domain expert. We restricted our evaluation to those outcomes deemed clinically important and did not include surrogate outcomes.

Outcomes of interest included:

- Mortality due to all causes
- Length of hospital and intensive care unit stay
- Medical morbidities (e.g., cardiac or pulmonary events)
- Duration of ventilation
- Quality of life, using any quality of life measure or any measure of symptom relief
- Optimization of treatment (e.g., ACE inhibitor maximization)
- Adverse events and complications associated with PAC use (Question 4), including, but not limited to
  - Pneumothorax
  - Bleeding
  - Arrhythmia
  - Infection
  - Insertion complications
  - Death
  - Urgent surgery

### Study designs of interest

For clinical outcomes, we included only randomized controlled trials, excluding nonrandomized prospective studies, noncomparative studies, and retrospective studies (including case-control studies). There was no minimum sample size requirement.

For adverse events, we also included studies of any design with at least than 500 patients with PACs. Review articles were also included for lists of adverse events and some estimates of rates of adverse events from primary studies that these reviews evaluated.

## Data Extraction

Items extracted included study year, country, setting, funding source, study design, eligibility criteria, and type of PAC use (see Appendix B for a sample data extraction form). For randomized controlled trials (RCTs), we recorded the method of randomization, allocation concealment, blinding, and whether results were reported on an intention-to-treat basis. Specific population characteristics included demographics such as age and sex, and baseline severity of disease. Details regarding PAC management, including who inserted PAC and the duration of PAC exposure were also extracted.

For each outcome of interest, baseline, followup, and change from baseline data were extracted, including information of statistical significance. For most outcomes, only data from the last reported time point was included. When outcome data were reported as overall outcomes, without a specific time point, the mean or median time of followup was used. All adverse event data were extracted.

## Quality Assessment

We assessed the methodological quality of studies based on predefined criteria. We used a 3-category grading system (A, B, C) to denote the methodological quality of each study. This grading system has been used in most of the previous evidence reports from the Tufts EPC as well as in evidence-based clinical practice guidelines (21;22). This system defines a generic grading system that is applicable to varying study designs including randomized and nonrandomized comparative trials, cohort, and case-control studies. For randomized trials, we mainly considered the methods used for randomization, allocation concealment, and blinding as well as the use of intention-to-treat analysis, the report of dropout rate and the extent to which valid primary outcomes were described, as well as clearly reported. Studies were not rejected due to poor quality.

- A (good)
  - Category A studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20 percent dropout; clear reporting of dropouts; and no obvious bias.
    For studies of adverse events, it must be a prospective design.
- B (fair/moderate)
  - Category B studies are susceptible to some bias, but not sufficient to invalidate the results. They do not meet all the criteria in category A because they have some deficiencies, but none likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
    For studies of adverse events, it must be a prospective design.
- C (poor)
  - Category C studies have significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information, or discrepancies in reporting.
    All retrospective studies of adverse events were graded C.

## Applicability Assessment

Applicability addresses the relevance of a given study to a population of interest. Every study applies certain eligibility criteria when selecting study subjects. Most of these criteria are explicitly stated (e.g., disease status, age, comorbidities). Some may be implicit or due to unintentional biases, such as those related to location (e.g., multicenter vs. single center, intensive care vs. all inpatients), years of PAC use, and other issues. The applicability of a study is dictated by the key questions, the populations, and the interventions that are of interest to this review, as opposed to those of interest to the original investigators.

To address this issue, we categorized studies within a target population into 1 of 3 levels of applicability that are defined as follows:

High | Sample is representative of Medicare population in relevant settings. Patients' age (older adult), gender, spectrum of disease severity and type, etc. are representative of population of interest. PACs were used within past 10 years (1997-2006).
Moderate | Sample is an important subgroup of population of interest. Possibly limited to a narrow or young age range, type of disease, gender etc. PACs were used within past 20 years (1987-2006).
Low | Sample represents only a narrow, atypical subgroup of population of interest.

## Data Synthesis

### Metaanalyses

Metaanalysis was performed to examine whether therapeutic management based on PAC monitoring led to improved patient outcomes compared to noninvasive and less invasive techniques, when sufficient data were available. We used the DerSimonian and Laird's random effects model for all syntheses (23). The random effects model assigns a weight to each study based both on the individual study variance and the between-study heterogeneity. Compared with the fixed effect model, the random effects model is more conservative in that it generally results in broader confidence intervals when between-study heterogeneity is present. We tested for heterogeneity using Cochran's Q and assessed its extent with I^2^, which evaluates the proportion of between study variability that is attributed to heterogeneity rather than chance (24;25).

#### Mortality outcome

For mortality, we used the random effects model for binary data to combine studies. Studies that reported mortality rates for both PAC and control groups were included in the metaanalysis. The odds ratio (OR) and its standard error (SE) were calculated for each study from the raw events data. Studies that reported only data on (adjusted or unadjusted) OR and SE were also included in the analysis with an assumption of symmetrical confidence intervals. When only exact P values were reported (instead of SE), we back-calculated the SE from the P value.

#### Length of stay

For the outcomes length of hospital stay and length of intensive care unit stay we used the random effects model for effect size (the mean between-group difference in the length of stay) to combine studies. Studies were included only if they reported sufficient data to estimate both the effect size and the SE of the effect size. When only exact p values were reported, we back-calculated the SE from the P value.

#### Subgroup Analyses

To explore potential reasons for differences of results across studies, we performed subgroup analyses by types of comparison (PAC vs. no PAC; PAC vs. CVP) for all metaanalyses.

## External Review

Five cardiologists and/or pulmonary and critical care medicine specialists kindly reviewed early drafts of this report. Each comment was addressed and responded to, and revisions were made. The authors of the report maintain full responsibility for the content and judgments made herewithin. The final report has not been endorsed report by the reviewers. Staff at CMS and AHRQ also provided comments, but the findings and conclusions do not necessarily represent the views of AHRQ or CMS. Therefore, no statement in this report should be construed as an official position of the Agency for Healthcare Research and Quality, the U.S. Department of Health and Human Services, or the Centers for Medicare and Medicaid Services.