# Introduction

The Center for Medicare & Medicaid Services (CMS) requested that the Tufts Medical Center Evidence-based Practice Center (Tufts EPC) conduct a technology assessment report on pulmonary artery catheter (PAC) monitoring in patients hospitalized in critical care settings. The primary goal of the report is to describe the utility of PAC monitoring with relevance to the relative effect and safety of PAC monitoring and how it affects outcomes in the Medicare population (i.e., people at least 65 years old) hospitalized in critical care settings.

The specific questions addressed are described at the end of the Introduction. Below is a narrative review of PAC monitoring and other devices or techniques that are currently used to assess cardiac output and volume status in critical care settings.

## Pulmonary artery catheter description

The PAC, also widely known as a Swan-Ganz catheter, is a flow-directed balloon flotation catheter introduced in the 1970s (1). Pulmonary artery catheterization has steadily evolved into a frequently employed method of bedside monitoring of cardiac output and volume status that does not yet have a suitable alternative for continually evaluating hemodynamic status (2). Although initially PAC was introduced in cardiac care units, it has frequently been used in a wide range of critical care settings because of its ability to assess hemodynamic status that can aid in disease diagnosis and guide fluid and therapeutic drug management in critically ill patients.

PAC measures cardiac output and pressures in the superior vena cava, right heart, and pulmonary artery. Left ventricular filling pressure can also be estimated by measuring pulmonary artery occlusive pressure (PAOP). In addition, modern catheters can evaluate cardiovascular hemodynamics and status, including mixed venous oxygen saturation, and right ventricular end-diastolic volume and right ventricular ejection fraction. These measurements are commonly used to evaluate critically ill patients' hemodynamic status, complementing clinical assessment and guiding therapy.

### Catheterization and measurement techniques

PAC is a multi-lumen plastic catheter, 110 to 150 cm long with a balloon located just proximal to the tip of the distal lumen. In the majority of catheters a thermistor, which measures temperature changes for the assessment of cardiac output, is located proximal to the balloon. Two additional lumens (right ventricular port and venous infusion port, if present) located at 19 cm and 30 cm from the tip reach the right ventricle and right atrium or superior vena cava. The PAC is connected to the monitoring equipment through a semi-rigid, noncompliant fluid-filled tube and pressure transducer. The movements in the transducer membrane generate electrical impulses that are amplified and transmitted to a monitor.

The PAC is usually inserted percutaneously through an introducer sheath into a major vein (jugular, subclavian, or femoral). It can also be inserted via a cut-down to the vein without an introducer. After insertion through the sheath, the balloon is slowly inflated with 1.5 cc of air and the catheter is floated through right side of the heart until it wedges in a branch of the pulmonary artery. The balloon is deflated and left in the pulmonary artery. The central pressures measured are PAOP, an indicator of left atrial pressure, the pulmonary artery pressure, the right atrial pressure, and the right ventricular pressure. The thermodilution technique allows cardiac output determination through infusion of cold saline into the right atrial lumen that mixes with blood. The resultant temperature changes are recorded by the thermistor at the tip of the catheter. Cardiac output allows estimation of stroke volume, a measure of cardiac performance. In addition, other measurements that can be provided by the PAC include mixed venous oxygen saturation and oxygen saturations in the right heart chambers, which can be used to assess for the presence of an intracardiac shunt, right atrial pressures and PAOP, which can be used to assess cardiac valve dysfunction. The systemic vascular resistance and pulmonary vascular resistance can also be calculated from other hemodynamic variables. In summary, PAC provides a comprehensive assessment of cardiovascular function.

### Pulmonary artery catheter uses

PAC is used as a diagnostic tool for the following conditions (among others): sepsis and septic shock; pulmonary edema; primary pulmonary hypertension; valvular disease; intracardiac shunts; cardiac tamponade; and pulmonary embolus. In addition to initial assessment of hemodynamic function, PAC can be kept in place for several days allowing evaluation of serial measurements to monitor hemodynamic status. It is thus used to monitor the following conditions (among others): acute myocardial infarction complicated by cardiogenic shock, right ventricular infarction, ventricular septal defect, or papillary muscle rupture; cardiac surgery and post-operative recovery; trauma complicated by multiorgan failure; major thermal injury; and assessment of response to fluid and vasodilator therapies.

## Potential clinical value and harms

### Potential clinical value

Soon after its introduction, PAC use in intensive care settings disseminated prior to rigorous evaluation of the effect of its use on clinical outcomes or cost savings. The ability of PAC to provide a wide range of variables that are used to assess hemodynamic status and to guide therapy is seen as beneficial in the intensive care setting. A systematic review in 1996 by Cooper et al. evaluated 34 randomized and nonrandomized studies and found that they were evenly split among those that found no benefit or worse outcomes with PAC and those showing benefit (3). Subsequent randomized trials and a large risk-adjusted nonrandomized study in the late 1990s came to differing conclusions regarding the value and safety of PAC in intensive care settings (4-7). In response, the Society of Critical Care Medicine convened a Consensus Conference (of clinical specialists), which stated that the published evidence on PAC was poor; however, there was a recommendation against a moratorium on PAC use, although the need for clinical trials was highlighted (8;9). Subsequent studies and opinion pieces have further cast doubt on the value of PAC (10-12). Dalen called for a moratorium on the use of PAC for routine monitoring of patients undergoing major surgery and in patients with acute myocardial infarction; he also called for randomized controlled trials to demonstrate their benefit (10). Additionally in 1997, National Heart Lung and Blood Institute (NHLBI) and Food and Drug Administration (FDA) convened a Pulmonary Artery Catheterization and Clinical Outcomes (PACCO) Workshop to develop a criteria for insertion of PAC (13). The proceedings of the workshop was published as a consensus statement that highlighted many areas in which the data were insufficient and this directly led to NHLBI funding for two of the important randomized trials (14;15).

In addition to the questionable clinical value of PAC in the controlled study setting, a common concern is that adequately measuring hemodynamic data is fraught with difficulties. Examples include errors in positioning the PAC such that alveolar rather than pulmonary venous pressure is measured, confounding of readings from positive pressure ventilation, and failure of PAOP to accurately measure left ventricular preload and other measures (12). The data obtained from PAC has to be accurately interpreted and acted upon.

Recent guidelines reflect a shift in recommendations. Both the 2002 ACC/AHA Guideline Update on Perioperative Cardiovascular Evaluation for Noncardiac Surgery and the 2003 American Society of Anesthesiologists Task Force on Pulmonary Artery Catheterization recommend against the routine use of PAC for perioperative care, but do recommend its use in various settings (16;17). The 2003 guidelines state that “the appropriateness of routine PAC depends on the combination of risks associated with the (a) patient, (b) surgery, and (c) practice setting (the latter referring to the risks from PAC introduced by practice conditions and staff circumstances)” (17).

Two recent systematic reviews of PAC in the ICU setting both came to similar conclusions (18;19). The reviews evaluated 11 and 13 overlapping randomized trials of PAC or no PAC use. Both found nearly identical odds of death regardless of intervention and no clinically or statistically significant difference in length of hospital stay. One review noted that PAC was associated with higher overall hospital costs in four US studies (18). The other found higher use of inotropes and intravenous vasodilators with PAC use (19).

PAC is a complex diagnostic test. Like any diagnostic test, it will only make a difference if the diagnostic information leads to a therapeutic strategy that can improve outcomes. Thus, the current results (and thus lack of need for use) may reflect the fact that there are no proven effective therapies for the acute heart failure. While the benefits of diuretics, is currently under-evaluated in terms of dosing and duration, etc, other therapies (ACE inhibitors, beta blockers) have chronic effects that are beneficial with little known about how to optimize their acute effects. In terms of technology evaluation of PAC use this is an important issue for two reasons: 1) new therapies for acute heart failure are under development; 2) new much less invasive or indwelling methods of measuring cardiac and pulmonary pressures are being introduced into the clinical setting.

However, it is useful to consider where current knowledge about the value of PAC fits in Dennis Fryback's and John Thornbury's hierarchical model of the efficacy of diagnostic testing (20). Very briefly, their model includes 6 levels of efficacy, or benefit to patients and society, that can be used to assess diagnostic tests. The levels include

1. Technical efficacy: whether the test does what it claims (e.g., measures volume status)
2. Diagnostic accuracy efficacy: how often the test is correct (e.g., sensitivity and specificity)
3. Diagnostic thinking efficacy: whether the test is judged helpful in making a diagnosis
4. Therapeutic efficacy: whether the test is judged helpful in planning management
5. Patient outcome efficacy: whether patients clinically improve after the test compared with not having the test
6. Societal efficacy: cost-effectiveness or cost-benefit analyses from the societal perspective.

When evaluating the potential clinical value of a test, it is helpful to consider the level of efficacy being considered. Depending on the test under consideration, and the value to the patients of knowing their diagnosis or of altering management, different levels of efficacy may be important. The use of PAC in an intensive care setting, after the first set of readings, primarily are used to plan management (level 4) with the expectation that this will improve patient outcomes by increasing the use of appropriate treatments (level 5).

### Potential harms

As an invasive procedure into the cardiopulmonary system, PAC is associated with potentially catastrophic adverse events. These will be discussed further under Question 4 regarding complications and adverse events. Broadly, the adverse events due to PAC can be categorized into those due to the invasive procedure, including hemorrhage, organ rupture, and loss of the guidewire; due to the pressure measurement techniques, including valvular and vascular damage, arrhythmias, and pulmonary injury; and due to the loss of skin integrity, including bleeding and infection. As described below, death, major morbidity (medical complications), and need for emergency major surgery are known risks.

## Key Questions

CMS requested a description of PAC and related devices, their indications, and a current systematic review of the evidence supporting their use. Specifically, they posed four questions for review, as follows.

Question 1: What types of devices and techniques are currently used to assess cardiac output and manage volume status in critical care settings (including operating and recovery rooms)?

Question 2: What are the specific indications for pulmonary artery catheter placement in critical care settings?

Question 3: Does therapeutic management of cardiac output and volume status based on pulmonary artery catheter monitoring in critical care settings lead to improved patient outcomes compared to noninvasive and less invasive techniques?

Question 4: What complications and adverse events associated with pulmonary artery catheter monitoring have been reported?