# Forest plot data

(Figures 1-3)

Figure 1 Metaanalysis of odds ratio of death, PAC vs. control

Category/Study | n/N (PAC) | n/N (Control) | OR | 95% Confidence Interval | Setting | Quality | Applicability
PAC vs. no PAC
ESCAPE (2005) | 10/206 | 11/207 | 0.91 | (0.4, 2.2) | CCU | A | M
Harvey (2005) | 346/506 | 333/507 | 1.13 | (0.9, 1.5) | MICU | A | W
Rhodes (2002)* | nd/96 | nd/105 | 0.96 | (0.5, 1.8) | ICU | A | W
Richard (2003) | 119/338 | 208/348 | 0.93 | (0.7, 1.3) | ICU | A | M
Guyatt (1991) | 10/16 | 9/17 | 1.48 | (0.4, 5.9) | M/SICU | C | M
Sandham (2003) | 78/997 | 77/997 | 1.01 | (0.7, 1.4) | SICU | A | M
Berlauk (1991) | 1/68 | 2/21 | 0.14 | (0.0, 1.7) | SICU | B | N
Valentine (1998) | 3/60 | 1/58 | 3.00 | (0.3, 29) | SICU | B | N
Bonazzi (2002) | 0/50 | 0/50 | 1.00 | (0.0, 51) | SICU | B | N
Pooled | | | 1.03 | (0.9, 1.2)
PAC vs. CVP
Schultz (1985) | 1/35 | 10/35 | 0.07 | (0.0, 0.6) | ICU | C | M
NHLBI (2006) | 141/513 | 128/487 | 1.06 | (0.8, 1.4) | ICU | A | N
Shoemaker (1988) | 10/30 | 7/30 | 1.64 | (0.5, 5.1) | SICU | B | N
Pearson (1989) | 2/198 | 0/41 | 1.06 | (0.1, 22) | SICU | C | M
Bender (1997) | 1/51 | 1/53 | 1.04 | (0.1, 17) | SICU | B | N
Isaacson (1990) | 1/49 | 0/53 | 3.31 | (0.1, 83) | SICU | B | N
Pooled | | | 0.96 | (0.5, 2.0)
Overall | | | 1.03 | (0.9, 1.2)

Figure 2 Metaanalyses of mean difference in hospital length of stay (LOS), PAC vs. control

Category/Study | LOS days (PAC) | LOS days (Control) | Difference Hospital LOS (days) | 95% Conf. Interval | Setting | Quality | Applicability
PAC vs. no PAC
ESCAPE (2005) | 9 | 8 | 0.4 | (-1.4, 2.2) | CCU | A | M
Richard (2003) | 14 | 14 | -0.4 | (-2.1, 1.3) | ICU | A | M
Guyatt (1991) | 10 | 8 | -2.2 | (-10, 5.8) | M/SICU | C | M
Sandham (2003) | 10 | 10 | | (-1.2, 1.2) | SICU | A | M
Bonazzi (2002) | 12 | 11 | 1 | (-0.6, 2.6) | SICU | B | N
Valentine (1998) | 13 | 13 | 0 | (-5.5, 5.5) | SICU | B | N
Berlauk (1991) | 19 | 15 | 3.5 | (-3.3, 10) | SICU | B | N
Pooled | | | | 0.24 (-0.5, 1.0)
PAC vs. CVP
Bender (1997) | 13 | 12 | 0.5 | (-3.2, 4.2) | SICU | B | N
Shoemaker (1988) | 25 | 22 | 3 | (-5.6, 11) | SICU | B | N
Isaacson (1990) | 10 | 9 | 0.8 | (-2.2, 3.8) | SICU | B | N
Pooled | | | 0.84 | (-1.4, 3.1)
Overall | | | 0.30 | (-0.4, 1.0)

Figure 3 Metaanalyses of mean difference in ICU length of stay, PAC vs. control

Category/Study | LOS days (PAC) | LOS days (Control) | Difference Hospital LOS (days) | 95% Conf. Interval | Setting | Quality | Applicability
PAC vs. no PAC
Richard (2003) | 12 | 12 | -0.30 | (-1.8, 1.2) | ICU | A | M
Valentine (1998) | 8 | 7 | 1 | (-1.7, 3.7) | SICU | B | N
Berlauk (1991) | 3 | 3 | 0.6 | (-0.6, 1.8) | SICU | B | N
Pooled | | | 0.33 | (-0.6, 1.2)
PAC vs. CVP
Wheeler (2006) | 16 | 16 | -0.5 | (-0.8, 0.8) | ICU | A | N
Pearson (1989) | 2 | 1 | 0.65 | (-0.4, 1.7) | SICU | C | M
Bender (1997) | 3 | 3 | 0.1 | (-1.0, 1.1) | SICU | B | N
Shoemaker (1988) | 16 | 12 | 4.3 | (-2.6, 11) | SICU | B | N
Isaacson (1990) | 2 | 3 | -0.6 | (-1.4, 0.2) | SICU | B | N
Pooled | | | -0.07 | (-0.7, 0.6)
Overall | | | 0.0 | (-0.5, 0.5)