# Rejected Articles

Anonymous. The SvO2 study: general design and results of the feasibility phase of a multicenter, randomized trial of three different hemodynamic approaches and two monitoring techniques in the treatment of critically ill patients. The SvO2 Collaborative Group. Controlled Clinical Trials. 1995. (UI 7743791). Report of study design.
Adams JG, Clifford EJ, Henry RS, Poulos E. Selective monitoring in abdominal aortic surgery. American Surgeon. 1993. (UI 8368660). AE, N<500.
Afessa B, Spencer S, Khan W, LaGatta M, Bridges L, Freire AX. Association of pulmonary artery catheter use with in-hospital mortality. Critical Care Medicine. 2001. (UI 11395590). No AE data.
Aikawa N, Sumiyama Y, Kusachi S, Hirasawa H, Oda S, Yamazaki Y. Use of antifungal agents in febrile patients nonresponsive to antibacterial treatment: the current status in surgical and critical care patients in Japan. Journal of Infection & Chemotherapy. 2002. (UI 12373487). AE, N<500.
Aitken LM. Reliability of measurements of pulmonary artery pressure obtained with patients in the 60 degrees lateral position. American Journal of Critical Care. 2000. (UI 10631390). AE, N<500.
Albert NM, Spear BT, Hammel J. Agreement and clinical utility of 2 techniques for measuring cardiac output in patients with low cardiac output. American Journal of Critical Care. 1999. (UI 9987544). AE, N<500.
Amshel CE, Palesty JA, Dudrick SJ. Are chest X-rays mandatory following central venous recatheterization over a wire?. American Surgeon. 1998. (UI 9619168). Not PAC.
Bach A, Bohrer H, Geiss HK. Safety of a guidewire technique for replacement of pulmonary artery catheters. Journal of Cardiothoracic & Vascular Anesthesia. 1992. (UI 1472669). AE, N<500.
Bach A, Stubbig K, Geiss HK. Infectious risk of replacing venous catheters by the guide-wire technique. Zentralblatt fur Hygiene und Umweltmedizin. 1992. (UI 1388616). AE, N<500.
Bernard GR, Luce JM, Sprung CL, Rinaldo JE, Tate RM, Sibbald WJ, Kariman K, Higgins S, Bradley R, Metz CA. High-dose corticosteroids in patients with the adult respiratory distress syndrome. New England Journal of Medicine. 1987. (UI 3317054). AE, N<500.
Berthelsen PG, Eldrup N, Nilsson LB, Rasmussen JP. Thermodilution cardiac output. Cold vs room temperature injectate and the importance of measuring the injectate temperature in the right atrium. Acta Anaesthesiologica Scandinavica. 2002. (UI 12366505). AE, N<500.
Bilen Z, Weinberg PF, Gowani Y, Cohen IL, Socaris S, Fein IA. Clinical utility and cost-effectiveness of protective sleeve pulmonary artery catheters. Critical Care Medicine. 1991. (UI 1902154). AE, N<500.
Bishop MH, Shoemaker WC, Appel PL, Meade P, Ordog GJ, Wasserberger J, Wo CJ, Rimle DA, Kram HB, Umali R. Prospective, randomized trial of survivor values of cardiac index, oxygen delivery, and oxygen consumption as resuscitation endpoints in severe trauma. Journal of Trauma-Injury Infection & Critical Care. 1995. (UI 7760409). AE, N<500.
Catheter-induced pulmonary arterial trauma: can it always be averted?. Stone JG, Khambatta HJ, McDaniel DD. Journal of Thoracic & Cardiovascular Surgery. 1983. (UI 6602913). AE, N<500.
Celoria G, Steingrub JS, Vickers-Lahti M, Teres D, Stein KL, Fink M, Friedmann P. Clinical assessment of hemodynamic values in two surgical intensive care units. Effects on therapy. Archives of Surgery. 1990. (UI 2378556). AE, N<500.
Chang MC, Black CS, Meredith JW. Volumetric assessment of preload in trauma patients: addressing the problem of mathematical coupling. Shock. 1996. (UI 8946646). AE, N<500.
Chang MC, Meredith JW, Kincaid EH, Miller PR. Maintaining survivors' values of left ventricular power output during shock resuscitation: a prospective pilot study. Journal of Trauma-Injury Infection & Critical Care. 2000. (UI 10912854). AE, N<500.
Chang MC, Mondy JS, Meredith JW, Holcroft JW. Redefining cardiovascular performance during resuscitation: ventricular stroke work, power, and the pressure-volume diagram. Journal of Trauma-Injury Infection & Critical Care. 1998. (UI 9751535). AE, N<500.
Chawla LS, Zia H, Gutierrez G, Katz NM, Seneff MG, Shah M. Lack of equivalence between central and mixed venous oxygen saturation. Chest. 2004. (UI 15596689). AE, N<500.
Chen YY, Yen DH, Yang YG, Liu CY, Wang FD, Chou P. Comparison between replacement at 4 days and 7 days of the infection rate for pulmonary artery catheters in an intensive care unit. Critical Care Medicine. 2003. (UI 12771602). AE, N<500.
Chittock DR, Dhingra VK, Ronco JJ, Russell JA, Forrest DM, Tweeddale M, Fenwick JC. Severity of illness and risk of death associated with pulmonary artery catheter use. Critical Care Medicine. 2004. (UI 15071376). No AE data.
Christoforidis D, Chassot PG, Mosimann F, Lienard D, Brunstein F, Bejko D, Lejeune FJ, Chiolero R. Isolated limb perfusion: distinct tourniquet and tumor necrosis factor effects on the early hemodynamic response. Archives of Surgery. 2003. (UI 12511144). AE, N<500.
Cieslinski G, Konrad T, Klepzig H. Comparison of calculated and measured mixed venous oxygen saturation in critically ill patients. Infusionstherapie und Transfusionsmedizin. 1995. (UI 8589593). AE, N<500.
Cobb DK, High KP, Sawyer RG, Sable CA, Adams RB, Lindley DA, Pruett TL, Schwenzer KJ, Farr BM. A controlled trial of scheduled replacement of central venous and pulmonary-artery catheters. New England Journal of Medicine. 1992. (UI 1522842). AE, N<500.
Cohen Y, Fosse JP, Karoubi P, Reboul-Marty J, Dreyfuss D, Hoang P, Cupa M. The ‘hands-off’ catheter and the prevention of systemic infections associated with pulmonary artery catheter: a prospective study. American Journal of Respiratory & Critical Care Medicine. 1998. (UI 9445311). AE, N<500.
Coles NA, Hibberd M, Russell M, Love T, Ory D, Field TS, Dec GW, Eagle KA. Potential impact of pulmonary artery catheter placement on short-term management decisions in the medical intensive care unit. American Heart Journal. 1993. (UI 8213436). AE, N<500.
Connors AF, Speroff T, Dawson NV, Thomas C, Harrell FE, Wagner D, Desbiens N, Goldman L, Wu AW, Califf RM, Fulkerson WJ, Vidaillet H, Broste S, Bellamy P, Lynn J, Knaus WA. The effectiveness of right heart catheterization in the initial care of critically ill patients. SUPPORT Investigators. JAMA. 1996. (UI 8782638). No AE data.
Cotter G, Moshkovitz Y, Kaluski E, Milo O, Nobikov Y, Schneeweiss A, Krakover R, Vered Z. The role of cardiac power and systemic vascular resistance in the pathophysiology and diagnosis of patients with acute congestive heart failure. European Journal of Heart Failure. 2003. (UI 12921805). AE, N<500.
Damen J. Ventricular arrhythmias during insertion and removal of pulmonary artery catheters. Chest. 1985. (UI 4017671). AE, N<500.
Damen J. Infectious complications of simultaneously inserted central venous and pulmonary artery catheters. Netherlands Journal of Surgery. 1987. (UI 3683940). No AE data.
Decailliot F, Cherqui D, Leroux B, Lanteri-Minet M, Ben SS, Husson E, Duvaldestin P, Stephan F. Effects of portal triad clamping on haemodynamic conditions during laparoscopic liver resection. British Journal of Anaesthesia. 2001. (UI 11517137). AE, N<500.
Del Guercio LR, Savino JA, Morgan JC. Physiologic assessment of surgical diagnosis-related groups. Annals of Surgery. 1985. (UI 3931595). AE, N<500.
Della RG, Costa MG, Coccia C, Pompei L, Pietropaoli P. Preload and haemodynamic assessment during liver transplantation: a comparison between the pulmonary artery catheter and transpulmonary indicator dilution techniques. European Journal of Anaesthesiology. 2002. (UI 12510905). AE, N<500.
Della RG, Costa MG, Pompei L, Coccia C, Pietropaoli P. Continuous and intermittent cardiac output measurement: pulmonary artery catheter versus aortic transpulmonary technique. British Journal of Anaesthesia. 2002. (UI 11990265). AE, N<500.
Diebel LN, Myers T, Dulchavsky S. Effects of increasing airway pressure and PEEP on the assessment of cardiac preload. Journal of Trauma-Injury Infection & Critical Care. 1997. (UI 9137243). AE, N<500.
Djaiani G, Karski J, Yudin M, Hynninen M, Fedorko L, Carroll J, Poonawala H, Cheng D. Clinical outcomes in patients undergoing elective coronary artery bypass graft surgery with and without utilization of pulmonary artery catheter-generated data. Journal of Cardiothoracic & Vascular Anesthesia. 2006. (UI 16750727). No AE data.
Dokainish H, Zoghbi WA, Lakkis NM, Al-Bakshy F, Dhir M, Quinones MA, Nagueh SF. Optimal noninvasive assessment of left ventricular filling pressures: a comparison of tissue Doppler echocardiography and B-type natriuretic peptide in patients with pulmonary artery catheters. Circulation. 2004. (UI 15123522). AE, N<500.
Durham RM, Neunaber K, Mazuski JE, Shapiro MJ, Baue AE. The use of oxygen consumption and delivery as endpoints for resuscitation in critically ill patients. Journal of Trauma-Injury Infection & Critical Care. 1996. (UI 8676421). AE, N<500.
Eisenberg PR, Hansbrough JR, Anderson D, Schuster DP. A prospective study of lung water measurements during patient management in an intensive care unit. American Review of Respiratory Disease. 1987. (UI 3307570). AE, N<500.
Eisenberg PR, Jaffe AS, Schuster DP. Clinical evaluation compared to pulmonary artery catheterization in the hemodynamic assessment of critically ill patients. Critical Care Medicine. 1984. (UI 6734221). AE, N<500.
Elliott CG, Zimmerman GA, Clemmer TP. Complications of pulmonary artery catheterization in the care of critically ill patients. A prospective study. Chest. 1979. (UI 510002). AE, N<500.
Ely EW, Smith AC, Chiles C, Aquino SL, Harle TS, Evans GW, Haponik EF. Radiologic determination of intravascular volume status using portable, digital chest radiography: a prospective investigation in 100 patients. Critical Care Medicine. 2001. (UI 11505116). AE, N<500.
Eyer S, Brummitt C, Crossley K, Siegel R, Cerra F. Catheter-related sepsis: prospective, randomized study of three methods of long-term catheter maintenance. Critical Care Medicine. 1990. (UI 2209033). AE, N<500.
Eyraud D, Benmalek F, Teugels K, Bertrand M, Mouren S, Coriat P. Does desflurane alter left ventricular function when used to control surgical stimulation during aortic surgery?. Acta Anaesthesiologica Scandinavica. 1999. (UI 10456814). AE, N<500.
Fleming A, Bishop M, Shoemaker W, Appel P, Sufficool W, Kuvhenguwha A, Kennedy F, Wo CJ. Prospective trial of supranormal values as goals of resuscitation in severe trauma. Archives of Surgery. 1992. (UI 1417482). AE, N<500.
Fong Y, Whalen GF, Hariri RJ, Barie PS. Utility of routine chest radiographs in the surgical intensive care unit. A prospective study. Archives of Surgery. 1995. (UI 7611867). AE, N<500.
Friese RS, Shafi S, Gentilello LM. Pulmonary artery catheter use is associated with reduced mortality in severely injured patients: a National Trauma Data Bank analysis of 53,312 patients. Critical Care Medicine. 2006. (UI 16607232). No AE data.
Garrison RN, Wilson MA, Matheson PJ, Spain DA. Preoperative saline loading improves outcome after elective, noncardiac surgical procedures. American Surgeon. 1996. (UI 8607583). No AE data.
Gattinoni L, Brazzi L, Pelosi P, Latini R, Tognoni G, Pesenti A, Fumagalli R. A trial of goal-oriented hemodynamic therapy in critically ill patients. SvO2 Collaborative Group. New England Journal of Medicine. 1995. (UI 7675044). No AE data.
Gilbert WM, Towner DR, Field NT, Anthony J. The safety and utility of pulmonary artery catheterization in severe preeclampsia and eclampsia. American Journal of Obstetrics & Gynecology. 2000. (UI 10871455). AE, N<500.
Girbes AR, Ligtenberg JJ, Sonneveld JP, Wierda JM. Prevention of hypotension after induction of anesthesia after preoperative tune-up. A preliminary report of the Groningen Tune-up Study. Netherlands Journal of Medicine. 1999. (UI 10399449). Preoperative PAC only.
Gray P, Sullivan G, Ostryzniuk P, McEwen TA, Rigby M, Roberts DE. Value of postprocedural chest radiographs in the adult intensive care unit. Critical Care Medicine. 1992. (UI 1424692). AE, N<500.
Hagley MT, Martin B, Gast P, Traeger SM. Infectious and mechanical complications of central venous catheters placed by percutaneous venipuncture and over guidewires. Critical Care Medicine. 1992. (UI 1395664). AE, N<500.
Harvey S, Stevens K, Harrison D, Young D, Brampton W, McCabe C, Singer M, Rowan K. An evaluation of the clinical and cost-effectiveness of pulmonary artery catheters in patient management in intensive care: a systematic review and a randomised controlled trial. Health Technology Assessment (Winchester, England). 2006. (UI 16904048). Duplicate publication.
Hayes MA, Timmins AC, Yau EH, Palazzo M, Hinds CJ, Watson D. Elevation of systemic oxygen delivery in the treatment of critically ill patients. New England Journal of Medicine. 1994. (UI 7993413). AE, N<500.
Hesdorffer CS, Milne JF, Meyers AM, Clinton C, Botha R. The value of Swan-Ganz catheterization and volume loading in preventing renal failure in patients undergoing abdominal aneurysmectomy. Clinical Nephrology. 1987. (UI 3442956). AE, N<500.
Hilton E, Haslett TM, Borenstein MT, Tucci V, Isenberg HD, Singer C. Central catheter infections: single- versus triple-lumen catheters. Influence of guide wires on infection rates when used for replacement of catheters. American Journal of Medicine. 1988. (UI 3400662). AE, N<500.
Holm C, Mayr M, Tegeler J, Horbrand F, Henckel von DG, Muhlbauer W, Pfeiffer UJ. A clinical randomized study on the effects of invasive monitoring on burn shock resuscitation. Burns. 2004. (UI 15555792). Not PAC.
Holmes DR, Califf RM, Van de WF, Berger PB, Bates ER, Simoons ML, White HD, Thompson TD, Topol EJ. Difference in countries' use of resources and clinical outcome for patients with cardiogenic shock after myocardial infarction: results from the GUSTO trial. Lancet. 1997. (UI 8996417). No AE data.
Horowitz HW, Dworkin BM, Savino JA, Byrne DW, Pecora NA. Central catheter-related infections: comparison of pulmonary artery catheters and triple lumen catheters for the delivery of hyperalimentation in a critical care setting. Jpen: Journal of Parenteral & Enteral Nutrition. 1990. (UI 2125642). AE, N<500.
Iafrati MD, Gordon G, Staples MH, Mackey WC, Belkin M, Diehl J, Schwartz S, Payne D, O'Donnell TF. Transesophageal echocardiography for hemodynamic management of thoracoabdominal aneurysm repair. American Journal of Surgery. 1993. (UI 8352412). AE, N<500.
Iberti TJ, Benjamin E, Gruppi L, Raskin JM. Ventricular arrhythmias during pulmonary artery catheterization in the intensive care unit. Prospective study. American Journal of Medicine. 1985. (UI 3976703). AE, N<500.
Kac G, Durain E, Amrein C, Herisson E, Fiemeyer A, Buu-Hoi A. Colonization and infection of pulmonary artery catheter in cardiac surgery patients: epidemiology and multivariate analysis of risk factors. Critical Care Medicine. 2001. (UI 11378606). AE, N<500.
Kaczmarek RG, Liu CH, Gross TP. Medical device surveillance: gender differences in pulmonary artery rupture after pulmonary artery catheterization. Journal of Women's Health. 2003. (UI 14670173). No denominator reported.
Katz JD, Cronau LH, Barash PG, Mandel SD. Pulmonary artery flow-guided catheters in the perioperative period. Indications and complications. JAMA. 1977. (UI 577248). AE, N<500.
Kavarana MN, Azimuddin K, Agarwal A, Balsano N, Cayten CG, Agarwal N. Hemodynamic monitoring in the elderly undergoing elective colon resection for cancer. American Surgeon. 2003. (UI 12769213). AE, N<500.
Kearns PJ. A controlled trial of scheduled replacement of central venous and pulmonary catheters. Jpen: Journal of Parenteral & Enteral Nutrition. 1993. (UI 8505839). Letter.
Kim DH, Haney CL, Van GG. Reduction of pulmonary edema after SAH with a pulmonary artery catheter-guided hemodynamic management protocol. Neurocritical Care. 2005. (UI 16159089). No AE data.
Kwolek CJ, Miller A, Stonebridge PA, Lavin P, Lewis KP, Tannenbaum GA, Gibbons GW, Pomposelli FB, Freeman DV, Campbell DR. Safety of saline irrigation for angioscopy: results of a prospective randomized trial. Annals of Vascular Surgery. 1992. (UI 1547080). AE, N<500.
Larson LO, Kyff JV. The cost-effectiveness of Oximetrix pulmonary artery catheters in the postoperative care of coronary artery bypass graft patients. Journal of Cardiothoracic Anesthesia. 1989. (UI 2520650). AE, N<500.
Leung JM, O'Kelly BF, Mangano DT. Relationship of regional wall motion abnormalities to hemodynamic indices of myocardial oxygen supply and demand in patients undergoing CABG surgery. Anesthesiology. 1990. (UI 2240670). AE, N<500.
Lin M, Yang YF, Chiang HT, Chang MS, Chiang BN, Cheitlin MD. Reappraisal of continuous positive airway pressure therapy in acute cardiogenic pulmonary edema. Short-term results and long-term follow-up. Chest. 1995. (UI 7750335). AE, N<500.
London MJ, Moritz TE, Henderson WG, Sethi GK, O'Brien MM, Grunwald GK, Beckman CB, Shroyer AL, Grover FL. Participants of the Veterans Affairs Cooperative Study Group on Processes SaOoCiCS. Standard versus fiberoptic pulmonary artery catheterization for cardiac surgery in the Department of Veterans Affairs: a prospective, observational, multicenter analysis. Anesthesiology. 2002. (UI 11964593). No AE data.
Maki DG, Stolz SS, Wheeler S, Mermel LA. A prospective, randomized trial of gauze and two polyurethane dressings for site care of pulmonary artery catheters: implications for catheter management. Critical Care Medicine. 1994. (UI 7956275). AE, N<500.
Martin C, Auffray JP, Saux P, Albanese J, Gouin F. The axillary vein: an alternative approach for percutaneous pulmonary artery catheterization. Chest. 1986. (UI 3769571). AE, N<500.
Martin RS, Norris PR, Kilgo PD, Miller PR, Hoth JJ, Meredith JW, Chang MC, Morris JA. Validation of stroke work and ventricular arterial coupling as markers of cardiovascular performance during resuscitation. Journal of Trauma-Injury Infection & Critical Care. 2006. (UI 16688052). AE, N<500.
Mayer SA, Lin J, Homma S, Solomon RA, Lennihan L, Sherman D, Fink ME, Beckford A, Klebanoff LM. Myocardial injury and left ventricular performance after subarachnoid hemorrhage. Stroke. 1999. (UI 10187879). AE, N<500.
Maynard N, Bihari D, Beale R, Smithies M, Baldock G, Mason R, McColl I. Assessment of splanchnic oxygenation by gastric tonometry in patients with acute circulatory failure. JAMA. 1993. (UI 8355382). AE, N<500.
McCourt KC, Elliott P, Mirakhur RK, McMurray TJ, Phillips AS, Cochrane D. Haemodynamic effects of rapacuronium in adults with coronary artery or valvular disease. British Journal of Anaesthesia. 1999. (UI 10690133). AE, N<500.
McLane C, Morris L, Holm K. A comparison of intravascular pressure monitoring system contamination and patient bacteremia with use of 48- and 72-hour system change intervals. Heart & Lung. 1998. (UI 9622407). AE, N<500.
McMichan JC, Baele PL, Wignes MW. Insertion of pulmonary artery catheters--a comparison of fiberoptic and nonfiberoptic catheters. Critical Care Medicine. 1984. (UI 6723336). AE, N<500.
Mermel LA, McCormick RD, Springman SR, Maki DG. The pathogenesis and epidemiology of catheter-related infection with pulmonary artery Swan-Ganz catheters: a prospective study utilizing molecular subtyping. American Journal of Medicine. 1991. (UI 1928165). AE, N<500.
Miller JA, Singireddy S, Maldjian P, Baker SR. A reevaluation of the radiographically detectable complications of percutaneous venous access lines inserted by four subcutaneous approaches. American Surgeon. 1999. (UI 9926744). AE, N<500.
Mimoz O, Rauss A, Rekik N, Brun-Buisson C, Lemaire F, Brochard L. Pulmonary artery catheterization in critically ill patients: a prospective analysis of outcome changes associated with catheter-prompted changes in therapy. Critical Care Medicine. 1994. (UI 8143466). AE, N<500.
Mishra M, Chauhan R, Sharma KK, Dhar A, Bhise M, Dhole S, Omar A, Kasliwal RR, Trehan N. Real-time intraoperative transesophageal echocardiography--how useful? Experience of 5,016 cases. Journal of Cardiothoracic & Vascular Anesthesia. 1998. (UI 9854658). No AE data.
Mishra M, Malhotra R, Mishra A, Meharwal ZS, Trehan N. Hemodynamic changes during displacement of the beating heart using epicardial stabilization for off-pump coronary artery bypass graft surgery. Journal of Cardiothoracic & Vascular Anesthesia. 2002. (UI 12486647). No AE data.
Mitchell JP, Schuller D, Calandrino FS, Schuster DP. Improved outcome based on fluid management in critically ill patients requiring pulmonary artery catheterization. American Review of Respiratory Disease. 1992. (UI 1586077). AE, N<500.
Morris AH, Chapman RH, Gardner RM. Frequency of wedge pressure errors in the ICU. Critical Care Medicine. 1985. (UI 4028767). AE, N<500.
Mullins RJ, Garrison RN. Fractional change in blood volume following normal saline infusion in high-risk patients before noncardiac surgery. Annals of Surgery. 1989. (UI 2730178). AE, N<500.
Murdoch SD, Cohen AT, Bellamy MC. Pulmonary artery catheterization and mortality in critically ill patients. British Journal of Anaesthesia. 2000. (UI 11064621). No AE data.
Myers ML, Austin TW, Sibbald WJ. Pulmonary artery catheter infections. A prospective study. Annals of Surgery. 1985. (UI 3882064). AE, N<500.
Nehme AE. Swan-Ganz catheter: comparison of insertion techniques. Archives of Surgery. 1980. (UI 7425831). AE, N<500.
O'Brien W, Karski JM, Cheng D, Carroll-Munro J, Peniston C, Sandler A. Routine chest roentgenography on admission to intensive care unit after heart operations: is it of any value?. Journal of Thoracic & Cardiovascular Surgery. 1997. (UI 9011682). No AE data.
O'Malley MK, Rhame FS, Cerra FB, McComb RC. Value of routine pressure monitoring system changes after 72 hours of continuous use. Critical Care Medicine. 1994. (UI 8062565). AE, N<500.
Palm S, Linstedt U, Petry A, Wulf H. Dose-response relationship of propofol on mid-latency auditory evoked potentials (MLAEP) in cardiac surgery. Acta Anaesthesiologica Scandinavica. 2001. (UI 11576053). AE, N<500.
Patel C, Laboy V, Venus B, Mathru M, Wier D. Acute complications of pulmonary artery catheter insertion in critically ill patients. Critical Care Medicine. 1986. (UI 3943335). AE, N<500.
Peters SG, Afessa B, Decker PA, Schroeder DR, Offord KP, Scott JP. Increased risk associated with pulmonary artery catheterization in the medical intensive care unit. Journal of Critical Care. 2003. (UI 14595569). No AE data.
Pierce ET, Pomposelli FB, Stanley GD, Lewis KP, Cass JL, LoGerfo FW, Gibbons GW, Campbell DR, Freeman DV, Halpern EF, Bode RH. Anesthesia type does not influence early graft patency or limb salvage rates of lower extremity arterial bypass. Journal of Vascular Surgery. 1997. (UI 9052557). No AE data.
Poeze M, Takala J, Greve JW, Ramsay G. Pre-operative tonometry is predictive for mortality and morbidity in high-risk surgical patients. Intensive Care Medicine. 2000. (UI 11089753). No AE data.
Polanczyk CA, Rohde LE, Goldman L, Cook EF, Thomas EJ, Marcantonio ER, Mangione CM, Lee TH. Right heart catheterization and cardiac complications in patients undergoing noncardiac surgery: an observational study. JAMA. 2001. (UI 11466096). No AE data.
Polonen P, Ruokonen E, Hippelainen M, Poyhonen M, Takala J. A prospective, randomized study of goal-oriented hemodynamic therapy in cardiac surgical patients. Anesthesia & Analgesia. 2000. (UI 10781452). No AE data.
Prachar H, Dittel M, Jobst C, Kiss E, Machacek E, Nobis H, Spiel R. Bacterial contamination of pulmonary artery catheters. Intensive Care Medicine. 1978. (UI 649839). AE, N<500.
Publication Committee for the VMAC Investigators (Vasodilatation in the Management of Acute CHF). Intravenous nesiritide vs nitroglycerin for treatment of decompensated congestive heart failure: a randomized controlled trial. JAMA. 2002. (UI 11911755). No AE data.
Ramsey SD, Saint S, Sullivan SD, Dey L, Kelley K, Bowdle A. Clinical and economic effects of pulmonary artery catheterization in nonemergent coronary artery bypass graft surgery. Journal of Cardiothoracic & Vascular Anesthesia. 2000. (UI 10794325). No AE data.
Rao TL, Jacobs KH, El-Etr AA. Reinfarction following anesthesia in patients with myocardial infarction. Anesthesiology. 1983. (UI 6650905). No AE data.
Raphael P, Cogbill TH, Dunn EL, Strutt PJ, Fraga MJ. Routine invasive hemodynamic monitoring does not increase risk of aortic graft infection. Heart & Lung. 1993. (UI 8449755). AE, N<500.
Resano FG, Kapetanakis EI, Hill PC, Haile E, Corso PJ. Clinical outcomes of low-risk patients undergoing beating-heart surgery with or without pulmonary artery catheterization. Journal of Cardiothoracic & Vascular Anesthesia. 2006. (UI 16750726). No AE data.
Roshchin SI, Berezov VM, Varlamov AM, Boch VK, Roshchina GN, Verzilov SN. Effects of various nitrates on pulmonary wedge pressure in acute myocardial infarction. Cor et Vasa. 1990. (UI 2126754). AE, N<500.
Sakr Y, Vincent JL, Reinhart K, Payen D, Wiedermann CJ, Zandstra DF, Sprung CL. Sepsis Occurrence in Acutely III Patients Investigators. Use of the pulmonary artery catheter is not associated with worse outcome in the ICU. Chest. 2005. (UI 16236948). AE, N<500.
Schiller WR, Bay RC, Garren RL, Parker I, Sagraves SG. Hyperdynamic resuscitation improves survival in patients with life-threatening burns. Journal of Burn Care & Rehabilitation. 1997. (UI 9063781). AE, N<500.
Senagore A, Waller JD, Bonnell BW, Bursch LR, Scholten DJ. Pulmonary artery catheterization: a prospective study of internal jugular and subclavian approaches. Critical Care Medicine. 1987. (UI 3539524). AE, N<500.
Shah MR, Hasselblad V, Stinnett SS, Kramer JM, Grossman S, Gheorghiade M, Adams KF, Swedberg K, Califf RM, O'Connor CM. Dissociation between hemodynamic changes and symptom improvement in patients with advanced congestive heart failure. European Journal of Heart Failure. 2002. (UI 12034155). No AE data.
Shah MR, O'Connor CM, Sopko G, Hasselblad V, Califf RM, Stevenson LW. Evaluation Study of Congestive Heart Failure and Pulmonary Artery Catheterization Effectiveness (ESCAPE): design and rationale. American Heart Journal. 2001. (UI 11275915). Report of study design.
Shah MR, Stinnett SS, McNulty SE, Gheorghiade M, Zannad F, Uretsky B, Adams KF, Califf RM, O'Connor CM. Hemodynamics as surrogate end points for survival in advanced heart failure: an analysis from FIRST. American Heart Journal. 2001. (UI 11376303). No AE data.
Shaw TJ. The Swan-Ganz pulmonary artery catheter. Incidence of complications, with particular reference to ventricular dysrhythmias, and their prevention. Anaesthesia. 1979. (UI 517718). AE, N<500.
Sise MJ, Hollingsworth P, Brimm JE, Peters RM, Virgilio RW, Shackford SR. Complications of the flow-directed pulmonary artery catheter: A prospective analysis in 219 patients. Critical Care Medicine. 1981. (UI 7214940). AE, N<500.
Sprung CL, Pozen RG, Rozanski JJ, Pinero JR, Eisler BR, Castellanos A. Advanced ventricular arrhythmias during bedside pulmonary artery catheterization. American Journal of Medicine. 1982. (UI 7058832). AE, N<500.
Stewart RD, Psyhojos T, Lahey SJ, Levitsky S, Campos CT. Central venous catheter use in low-risk coronary artery bypass grafting. Annals of Thoracic Surgery. 1998. (UI 9800825). No AE data.
Szakmany T, Toth I, Kovacs Z, Leiner T, Mikor A, Koszegi T, Molnar Z. Effects of volumetric vs. pressure-guided fluid therapy on postoperative inflammatory response: a prospective, randomized clinical trial. Intensive Care Medicine. 2005. (UI 15812629). Not PAC.
Tuchschmidt J, Fried J, Astiz M, Rackow E. Elevation of cardiac output and oxygen delivery improves outcome in septic shock. Chest. 1992. (UI 1623756). Not PAC.
Tuman KJ, McCarthy RJ, Spiess BD, DaValle M, Hompland SJ, Dabir R, Ivankovich AD. Effect of pulmonary artery catheterization on outcome in patients undergoing coronary artery surgery. Anesthesiology. 1989. (UI 2913857). No AE data.
Wall MH, MacGregor DA, Kennedy DJ, James RL, Butterworth J, Mallak KF, Royster RL. Pulmonary artery catheter placement for elective coronary artery bypass grafting: before or after anesthetic induction?. Anesthesia & Analgesia. 2002. (UI 12031997). AE, N<500.
Whittemore AD, Clowes AW, Hechtman HB, Mannick JA. Aortic aneurysm repair. Reduced operative mortality associated with maintenance of optimal cardiac performance. Annals of Surgery. 1980. (UI 7416834). AE, N<500.
Wilson J, Woods I, Fawcett J, Whall R, Dibb W, Morris C, McManus E. Reducing the risk of major elective surgery: randomised controlled trial of preoperative optimisation of oxygen delivery. BMJ. 1999. (UI 10213716). AE, N<500.
Yu DT, Platt R, Lanken PN, Black E, Sands KE, Schwartz JS, Hibberd PL, Graman PS, Kahn KL, Snydman DR, Parsonnet J, Moore R, Bates DW, AMCC Sepsis Project Working Group. Relationship of pulmonary artery catheter use to mortality and resource utilization in patients with severe sepsis. Critical Care Medicine. 2003. (UI 14668609). No AE data.
Yu M, Levy MM, Smith P, Takiguchi SA, Miyasaki A, Myers SA. Effect of maximizing oxygen delivery on morbidity and mortality rates in critically ill patients: a prospective, randomized, controlled study. Critical Care Medicine. 1993. (UI 8504649). AE, N<500.
Yu M, Takanishi D, Myers SA, Takiguchi SA, Severino R, Hasaniya N, Levy MM, McNamara JJ. Frequency of mortality and myocardial infarction during maximizing oxygen delivery: a prospective, randomized trial. Critical Care Medicine. 1995. (UI 7774212). AE, N<500.
Ziegler DW, Wright JG, Choban PS, Flancbaum L. A prospective randomized trial of preoperative ‘optimization’ of cardiac function in patients undergoing elective peripheral vascular surgery. Surgery. 1997. (UI 9308617). Preoperative PAC only.
Zion MM, Balkin J, Rosenmann D, Goldbourt U, Reicher-Reiss H, Kaplinsky E, Behar S. Use of pulmonary artery catheters in patients with acute myocardial infarction. Analysis of experience in 5,841 patients in the SPRINT Registry. SPRINT Study Group. Chest. 1990. (UI 2245670). No AE data.