# Articles evaluated

Author | Title | Date | UI/PMID | Journal | Topic
Bender JS | Routine pulmonary artery catheterization does not reduce morbidity and mortality of elective vascular surgery: results of a prospective, randomized trial | 1997 | 9339929 | Annals of Surgery | Clinical outcome
Berlauk JF | Preoperative optimization of cardiovascular hemodynamics improves outcome in peripheral vascular surgery. A prospective, randomized clinical trial | 1991 | 1929610 | Annals of Surgery | Clinical outcome
Binanay C, ESCAPE | Evaluation study of congestive heart failure and pulmonary artery catheterization effectiveness: the ESCAPE trial | 2005 | 16204662 | JAMA | Clinical outcome
Bonazzi M | Impact of perioperative haemodynamic monitoring on cardiac morbidity after major vascular surgery in low risk patients. A randomised pilot trial | 2002 | 12027474 | European Journal of Vascular & Endovascular Surgery | Clinical outcome
Guyatt G | A randomized control trial of right-heart catheterization in critically ill patients. Ontario Intensive Care Study Group | 1991 | 10147952 | Journal of Intensive Care Medicine | Clinical outcome
Harvey S | Assessment of the clinical effectiveness of pulmonary artery catheters in management of patients in intensive care (PAC-Man): a randomised controlled trial | 2005 | 16084255 | Lancet | Clinical outcome
Isaacson IJ | The value of pulmonary artery and central venous monitoring in patients undergoing abdominal aortic reconstructive surgery: a comparative study of two selected, randomized groups | 1990 | 2243411 | Journal of Vascular Surgery | Clinical outcome
Joyce WP | The role of central haemodynamic monitoring in abdominal aortic surgery. A prospective randomised study | 1990 | 2279574 | European Journal of Vascular Surgery | Clinical outcome
Pearson KS | A cost/benefit analysis of randomized invasive monitoring for patients undergoing cardiac surgery. | 1989 | 2505641 | Anesthesia & Analgesia | Clinical outcome
Rhodes A | A randomised, controlled trial of the pulmonary artery catheter in critically ill patients | 2002 | 11904653 | Intensive Care Medicine | Clinical outcome
Richard C | Early use of the pulmonary artery catheter and outcomes in patients with shock and acute respiratory distress syndrome: a randomized controlled trial | 2003 | 14645314 | JAMA | Clinical outcome
Sandham JD | A randomized, controlled trial of the use of pulmonary-artery catheters in high-risk surgical patients | 2003 | 12510037 | New England Journal of Medicine | Clinical outcome
Schultz RJ | The role of physiologic monitoring in patients with fractures of the hip | 1985 | 3989888 | Journal of Trauma-Injury Infection & Critical Care | Clinical outcome
Shoemaker WC | Prospective trial of supranormal values of survivors as therapeutic goals in high-risk surgical patients | 1988 | 3191758 | Chest | Clinical outcome
Shoemaker WC | The efficacy of central venous and pulmonary artery catheters and therapy based upon them in reducing mortality and morbidity | 1337 | 2222172 | Archives of Surgery | Clinical outcome
Valentine RJ | Effectiveness of pulmonary artery catheters in aortic surgery: a randomized trial | 1998 | 9510275 | Journal of Vascular Surgery | Clinical outcome
Wheeler AP | Pulmonary-artery versus central venous catheter to guide treatment of acute lung injury | 2006 | 16714768 | New England Journal of Medicine | Clinical outcome
Bossert T | Swan-Ganz catheter-induced severe complications in cardiac surgery: right ventricular perforation, knotting, and rupture of a pulmonary artery | 2006 | 16684066 | Journal of Cardiac Surgery | Adverse events
Boyd KD | A prospective study of complications of pulmonary artery catheterizations in 500 consecutive patients | 1983 | 6884097 | Chest | Adverse events
Cohen MG | Pulmonary artery catheterization in acute coronary syndromes: insights from the GUSTO IIb and GUSTO III trials | 2005 | 15866250 | American Journal of Medicine | Adverse events
Damen J | A prospective analysis of 1,400 pulmonary artery catheterizations in patients undergoing cardiac surgery | 1986 | 3766094 | Acta Anaesthesiologica Scandinavica | Adverse events
Kearney TJ | Pulmonary artery rupture associated with the Swan-Ganz catheter | 1995 | 7587440 | Chest | Adverse events
Lopez-Sendon J | Right ventricular infarction as a risk factor for ventricular fibrillation during pulmonary artery catheterization using Swan-Ganz catheters | 1990 | 2296867 | American Heart Journal | Adverse events
Shah KB | A review of pulmonary artery catheterization in 6,245 patients | 1984 | 6476435 | Anesthesiology | Adverse events
Webster CS | A prospective clinical audit of central venous catheter use and complications in 1000 consecutive patients | 2003 | 12635401 | Anaesthesia & Intensive Care | Adverse events