# MEDLINE search strategy

## MEDLINE 1966-September Week 2 2006

# History | Search Results
1 (artery adj2 catheter$).tw. | 3994
2 pulmonary.mp. | 348197
3 1 and 2 | 2557
4 exp Catheterization, Swan-Ganz/ | 1620
5 exp Thermodilution/ | 1841
6 S-G catheter.mp. | 2
7 Swan-Ganz.mp. | 3092
8 or/3-7 | 6338
9 limit 8 to humans | 5494
10 limit 9 to “all adult (19 plus years)” | 3527
11 9 not 10 | 1967
12 limit 11 to “all child (0 to 18 years)” | 195
13 9 not 12 | 5299
14 limit 13 to english language | 4323
15 limit 14 to (guideline or meta analysis or practice guideline or “review”) | 359
16 14 not 15 | 3964
17 follow-up studies/ | 339797
18 (follow-up or followup).tw. | 347111
19 exp Case-Control Studies/ | 339945
20 (case adj20 control).tw. | 46309
21 exp Longitudinal Studies/ | 563121
22 longitudinal.tw. | 69039
23 (random$ or rct).tw. | 369848
24 exp Randomized Controlled Trials/ | 48201
25 exp random allocation/ | 58870
26 exp Double-Blind Method/ | 91075
27 exp Single-Blind Method/ | 10636
28 randomized controlled trial.pt. | 234619
29 clinical trial.pt. | 457763
30 multicenter study.pt. | 83156
31 controlled clinical trials/ | 3400
32 (clin$ adj trial$).tw. | 106615
33 ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw. | 87186
34 exp PLACEBOS/ | 25749
35 placebo$.tw. | 100882
36 exp Cohort Studies/ | 609650
37 cohort.tw. | 87211
38 exp Research Design/ | 217545
39 exp Evaluation Studies/ | 597331
40 exp Prospective Studies/ | 219773
41 exp Comparative Study/ | 1349008
42 or/17-39 | 3050006
43 16 and 42 | 1918
44 limit 43 to comment and (letter or editorial).pt. | 61
45 limit 43 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or news or newspaper article or patient education handout or periodical index) | 67
46 43 not (44 or 45) | 1811