# Simulation results

We simulated hypothetical cohorts of 100,000 people suspected of OSAHS. The baseline analyses focused on middle-aged-people (i.e., people aged 50 years old) who are referred for sleep studies. As discussed in the methods, the majority of the literature pertains to middle-aged people. Because Medicare beneficiaries are of interest, we also present results for a different hypothetical cohort, composed of 70 year olds. In the sections below we discuss the simulation results and present sensitivity analyses.

The assumptions behind the modeled strategies and the probabilities that are being used, as well as details on definitions of the various health states are presented in the methods section in detail.

## Proportion of people who are offered CPAP

Here we describe the proportion of people who have completed a technically adequate CPAP level titration study. Essentially, these are people with a positive OSAHS diagnosis.

### Baseline analyses

Table 8 depicts the results of the simulations for the baseline analyses. The two reference strategies where none or all of the participants are offered CPAP treatment will not be discussed further, and they are included for comparison.

Most people (62 percent of the whole cohort) will be offered CPAP in strategy 5 (home diagnosis, and split-night PSG for negative home tests). In this strategy 99 percent of people with OSAHS and 20 percent of people without OSAHS will be offered CPAP.

The most false negatives, 19 percent, are expected with Strategy 4 (home testing, and further verification of positive cases with split-night studies in the lab). The proportion of people who will be offered CPAP without having OSAHS is low in this strategy (“false positives”, 1 percent), because two tests are applied serially.

Management completely outside of the sleep lab would result in 56 percent of the whole cohort being offered CPAP (91 percent of people with OSAHS and 15 percent of people without the disease). If split-night PSG (strategy 3) is used, it is expected that 89 percent of people with- and 6 percent of those without OSAHS will be offered CPAP.

Table 8 Baseline analyses: Proportion offered CPAP in a hypothetical cohort of 100,000 middle-aged people suspected of OSAHS

Strategy (for diagnosis and CPAP level titration) | Number (%)
Strategy (for diagnosis and CPAP level titration) | Whole cohort | Among those with OSAHS | Among those without OSAHS
1. None started on CPAP | 0 (0) | 0 (0) | 0 (0)
2. Full night PSG, treatment PSG | 54,000 (54) | 54,000 (100) | 0 (0)
3. Split-night PSG | 50,881 (51) | 48,101 (89) | 2,780 (6)
4. Home diagnosis, split-night PSG to verify positive cases | 44,118 (44) | 43,704 (81) | 414 (1)
5. Home diagnosis, split-night PSG in all negative cases | 62,703 (62) | 53,462 (99) | 9,241 (20)
6. Home diagnosis, home CPAP titration | 56,035 (56) | 49,140 (91) | 6,895 (15)
7. All started on CPAP | 100,000 (100) | 54,000 (100) | 46,000 (100)

CPAP: continuous positive airway pressure; OSAHS: Obstructive sleep apnea-hypopnea syndrome (see methods for definition).

### Analyses for older adults

Table 9 shows the corresponding estimations among people who are older (70 years of age). As discussed in the Methods section, we assumed that the prevalence of OSAHS is 27 percent of older adults who are being referred for evaluation. This is because of the increased prevalence of other conditions that must be differentiated from OSAHS, and because of the relative dissociation of OSAHS with characteristic symptoms and signs among older adults (see methods section for rationale on this assumption). Among older adults, we also expect the specificity of home diagnosis to be compromised (it can be argued that only a detailed PSG study in a specialized facility can differentiate between conditions that mimic OSAHS – see methods section).

Table 9 Baseline analyses: Proportion offered CPAP in a hypothetical cohort of 100,000 older adults suspected of OSAHS

Strategy (for diagnosis and CPAP level titration) | Number (%)
Strategy (for diagnosis and CPAP level titration) | Whole cohort | Among those with OSAHS | Among those without OSAHS
1. None started on CPAP | 0 (0) | 0 (0) | 0 (0)
2. Full night PSG, treatment PSG | 27,000 (27) | 27,000 (100) | 0 (0)
3. Split-night PSG | 28,462 (28) | 24,050 (89) | 4,412 (6)
4. Home diagnosis, split-night PSG to verify positive cases | 23,165 (23) | 21,852 (81) | 1,313 (2)
5. Home diagnosis, split-night PSG in all negative cases | 51,682 (51) | 26,731 (99) | 24,951 (34)
6. Home diagnosis, home CPAP titration | 46,455 (46) | 24,570 (91) | 21,885 (30)
7. All started on CPAP | 100,000 (100) | 27,000 (100) | 73,000 (100)

CPAP: continuous positive airway pressure; OSAHS: Obstructive sleep apnea-hypopnea syndrome (see methods for definition). Older adults are Medicare beneficiaries aged 70 years old.

Letting strategies 1 and 7 aside, strategy 5 (home diagnosis, and split-night PSG for negative home tests) would result in most people offered CPAP (51 percent of the whole cohort; Table 9). Although only 1 percent of “false negatives” (people with OSAHS who are not offered CPAP) is expected in strategy 5, 34 percent of those without OSAHS would be offered CPAP (“false positives”).

Strategy 6 (management outside the sleep labs) would have 9% “false negatives” and approximately 30 percent “false positives”.

In contrast, strategies that incorporate facility-based PSG or split-night PSG have considerably lower rates of false positive diagnoses. Twenty-seven, 28 and 23 percent of people will be offered CPAP treatment when facility-based PSG, split-night PSG or a verification of positive home diagnosis with split-night PSG is used (strategies 2, 3 and 4, respectively).

#### Sensitivity analyses

We conducted wide range sensitivity analyses to assess the robustness of the findings. Here, we present the results of univariate analyses for those variables that had some influence on the proportion of people who will be offered CPAP, for any of the strategies.

#### Prevalence (prev)

Figure 6 shows the effects of varying prevalence. When people are managed with facility-based PSG the diagnosis is “optimal” (because its sensitivity and specificity are assumed to be 100% in the main analyses; strategy 2). Strategy 2 in Figure 6 may serve as a reference for strategies which use split-night PSG only (strategy 3), a combination of portable monitoring and split-night PSG (strategies 4 and 5), and portable monitoring (strategy 6), respectively.

In the sensitivity analyses, in strategy 5 (home diagnosis, and split-night PSG for negative home tests) the proportion of people who are offered CPAP is always higher that that of strategy 2 (because of the increased number of false positives). Furthermore, as the true prevalence becomes less than approximately 60 percent, more people will be offered CPAP in strategy 5 compared to strategy 2. This is because of the increasing number of false positives diagnoses of OSAHS. In strategy 4, all positive diagnoses with portable home monitors are further verified by split-night PSG studies. The number of false positive diagnoses remains low, and the proportion of people starting on CPAP is consistently lower that that of strategies 2, 3, 5 and 6.

Figure 6 Sensitivity analysis on prevalence: proportion of people who are offered CPAP in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The number on the right hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 6. Sensitivity analysis on prevalence: proportion of people who are offered CPAP in a hypothetical cohort of 100,000 participants

#### Probability of no showing up for the firs diagnostic PSG or the first split night PSG (pNoShow_PSG and pNoShow_SpNPSG)

Figure 7 illustrates the corresponding sensitivity analyses. As the number of people who do not show up for the first lab exam increases, the proportion of people started on CPAP drops in strategies 2, 3 and 5. Strategy 5 is least affected, because only those with negative home testing are referred to the lab for further diagnostic evaluation.

Figure 7 Sensitivity analysis on the probability of no showing up for a study in the lab: proportion of people who are offered CPAP in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The number on the right hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 7. Sensitivity analysis on the probability of no showing up for a study in the lab: proportion of people who are offered CPAP in a hypothetical cohort of 100,000 participants

#### Sensitivity of facility-based polysomnography (S_PSG)

Figure 8 illustrates the effects of varying sensitivity of facility-based PSG. This analysis affects only strategy 2 (management with facility-based PSG and titration of CPAP levels in the sleep lab in a different night).

Figure 8 Sensitivity analysis on the sensitivity of facility-based PSG to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The number on the right hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 8. Sensitivity analysis on the sensitivity of facility-based PSG to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

#### Specificity of facility-based polysomnography (C_PSG)

Figure 9 illustrates the effects of varying specificity of facility-based PSG. This analysis affects only strategy 2 (management with facility-based PSG and titration of CPAP levels in the sleep lab in a different night).

Figure 9 Sensitivity analysis on the specificity of facility-based PSG to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The number on the right hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 9. Sensitivity analysis on the specificity of facility-based PSG to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

#### Sensitivity of split-night polysomnography (S_SpNPSG)

Figure 10 illustrates the effects of varying sensitivity for split-night PSG. This variable affects only strategies 3, 4 and 5, where split-night studies are used (alone or in combination with portable monitors). In these three strategies, the proportion of people who are offered CPAP changes by less than 10 percent along the range of values assumed in the sensitivity analysis (increases with increasing sensitivity values). Strategy 5 is the least affected of the three.

Figure 10 Sensitivity analysis on the sensitivity of split-night studies to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The number on the left hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 10. Sensitivity analysis on the sensitivity of split-night studies to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

#### Specificity of split-night polysomnography (C_SpNPSG)

Figure 11 illustrates the effects of varying specificity for split-night PSG. This variable affects only strategies 3, 4 and 5 (where split-night studies are used, alone or in combination with portable monitors, respectively). When the specificity of split-night studies decreases, the proportion of false positive diagnoses increases. As a consequence, the proportion of people who are offered CPAP becomes larger.

Note that strategy 4 is least affected in this sensitivity analysis, and that strategies 3 and 5 are most affected. This is because in strategy 4 the number of “false positives” is tightly controlled (through the serial verification of a positive diagnosis with two tests).

Figure 11 Sensitivity analysis on the specificity of split-night studies to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The number on the right hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 11. Sensitivity analysis on the specificity of split-night studies to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

#### Sensitivity of portable home monitors (S_HomeDx)

Figure 12 illustrates the effects of varying sensitivity of portable monitors. This variable affects only strategies 4, 5, and 6 where portable home monitoring is used. Overall, the proportion of people offered CPAP changes by less than 10 percent along the range of values in the sensitivity analysis.

Figure 12 Sensitivity analysis on the sensitivity of portable monitors to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The number on the right hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 12. Sensitivity analysis on the sensitivity of portable monitors to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

#### Specificity of portable home monitors (C_HomeDx)

Figure 13 illustrates the effects of varying specificity for the portable monitors. This variable affects only strategies 4, 5 and 6 where portable home monitoring is used. When the specificity of the portable monitors decreases, the proportion of false positive diagnoses increases. As a consequence, the proportion of people who are offered CPAP becomes larger.

Note that strategies 5 and 6 are most affected in this sensitivity analysis. Strategy 4 applies an additional test (split-night studies) to people who have positive home monitoring results, and this reduces the number of false positive diagnoses.

Figure 13 Sensitivity analysis on the specificity of portable monitors to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The number on the left hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 13. Sensitivity analysis on the specificity of portable monitors to detect OSAHS: proportion of people offered CPAP in a hypothetical cohort of 100,000 participants

#### Other variables

Sensitivity analyses of the remaining variables had little impact on this outcome.

#### Overview of univariate sensitivity analyses

Figure 14 provides an overview of the univariate sensitivity analyses. The figure summarizes the four variables that have the most profound effect on the corresponding strategies in the univariate sensitivity analyses. All other variables have even smaller influence.

Figure 14 Summary (“tornado” graph) of the variables with the greatest impact on the proportion of people offered CPAP per strategy in the univariate sensitivity analyses

Key: (auto)CPAP: (automated) continuous positive airway pressure titration; C_[PSG|SpNPSG|HomeDx]: specificity of [PSG|SpNPSG|HomeDx]; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; pNoShow_[PSG|SpNPSG]: probability of no showing up for the first diagnostic PSG or the first split-night PSG study]; prev: prevalence; PSG: polysomnography; pTreatInconcl: probability to start on CPAP if pressure level titration is technically inadequate, but a positive diagnosis of OSAHS exists; S_[PSG|SpNPSG|HomeDx]: sensitivity of [PSG|SpNPSG|HomeDx]; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The “all on CPAP” and “none on CPAP” strategies (1 and 7, respectively) are not shown, because they are not affected by the sensitivity analyses.

The length of each bar represents the change in the outcome for each strategy, when the corresponding variable is varied throughout its whole range in the univariate sensitivity analyses. Only the four more influential variables are shown for each strategy. Because variables are ordered by diminishing influence in each strategy, the image resembles a small tornado, hence the name “tornado” graph.

Figure 14. Summary (“tornado” graph) of the variables with the greatest impact on the proportion of people offered CPAP per strategy in the univariate sensitivity analyses

## Time to diagnosis with a sleep study

### Baseline analyses

Table 10 shows the average time to (final) diagnosis of OSAHS with a sleep study. The average time to diagnosis is the same, irrespective of whether this is positive or negative, accurate or inaccurate. Participants in the two extreme strategies (strategy 1 – “all on CPAP” and strategy 7 – “None on CPAP”) do not receive any testing for OSAHS throughout the whole follow-up period – therefore this outcome is not meaningful to assess here.

Home diagnosis with portable monitors results in the fastest diagnosis (after approximately 2 weeks on average). The average time to diagnosis increases for strategies that rely more heavily on the sleep labs for the management of these patients, and ranges from approximately 14 weeks in strategy 2 to approximately 4 weeks in strategy 5.

Table 10 Baseline analyses: time to (final) diagnosis of OSAHS with a sleep study in a hypothetical cohort of 100,000 middle-aged people suspected of OSAHS

Strategy (for diagnosis and CPAP titration) | Time (Weeks)
Strategy (for diagnosis and CPAP titration) | Whole cohort | Among those with OSAHS | Among those without OSAHS
1. None started on CPAP | NA^a^ | NA^a^ | NA^a^
2. Full night PSG, treatment PSG | 13.6 | 13.6 | 13.6
3. Split-night PSG | 9.8 | 9.8 | 9.8
4. Home diagnosis, split-night PSG to verify positive cases | 4.8 | 4.8 | 4.8
5. Home diagnosis, split-night PSG in all negative cases | 3.8 | 3.8 | 3.8
6. Home diagnosis, home CPAP titration | 2.1 | 2.1 | 2.1
7. All started on CPAP | NA^a^ | NA^a^ | NA^a^

CPAP: continuous positive airway pressure; NA: not applicable; OSAHS: Obstructive sleep apnea-hypopnea syndrome (see methods for definition).

a No diagnostic assessment is performed in these strategies

### Analyses for older adults

Table 11 shows the corresponding analyses among older adults (Medicare beneficiaries, aged 70 years). The results are very similar to findings among middle-aged people. The small differences with the average times shown in the previous analysis are attributable to adjustments in the average waiting time for a sleep study in the lab setting secondary to changes in the total workload of the sleep labs in each strategy.

It is interesting to note that strategy 5 (screen with portable monitors and further evaluation of all negative diagnoses in the sleep labs) is expected to result in slightly longer average time to diagnosis compared to strategy 4 (screen with portable monitors and verification of all positive diagnoses in the sleep labs), i.e., 4.4 weeks versus 4.1 weeks, respectively. The ranking of these strategies was the opposite among younger people (3.8 weeks for strategy 5 and 4.8 weeks for strategy 4; Table 10). This is because the prevalence of OSAHS is assumed smaller among older adults, increasing the number of negative home diagnoses and the workload of the sleep labs in strategy 5.

Table 11 Baseline analyses: time to (final) diagnosis of OSAHS with a sleep study in a hypothetical cohort of 100,000 older adults suspected of OSAHS

Strategy (for diagnosis and CPAP titration) | Time (Weeks)
Strategy (for diagnosis and CPAP titration) | Whole cohort | Among those with OSAHS | Among those without OSAHS
1. None started on CPAP | NA a | NA a | NA a
2. Full night PSG, treatment PSG | 11.3 | 11.3 | 11.3
3. Split-night PSG | 9.8 | 9.8 | 9.8
4. Home diagnosis, split-night PSG to verify positive cases | 4.0 | 4.0 | 4.0
5. Home diagnosis, split-night PSG in all negative cases | 4.5 | 4.5 | 4.5
6. Home diagnosis, home CPAP titration | 2.1 | 2.1 | 2.1
7. All started on CPAP | NA^a^ | NA^a^ | NA^a^

CPAP: continuous positive airway pressure; NA: not applicable; OSAHS: Obstructive sleep apnea-hypopnea syndrome (see methods for definition). Older adults are Medicare beneficiaries aged 70 years old.

a No diagnostic assessment is performed in these strategies

### Sensitivity analyses

We conducted wide range sensitivity analyses to assess the robustness of the findings. Here, we present the results of univariate analyses for the variable that had some influence on the time until first diagnosis, for any of the strategies.

#### Average waiting time per sleep study in the sleep laboratories (Dt_Lab)

The single most influential variable for this outcome is the length of the queue in the sleep labs. Figure 15 illustrates its effects.

Note that the mean waiting times for strategies 3 and 4 are calculated from those in strategy 2 based on the expected total number of sleep studies in the sleep labs with each strategy. See Appendix B for a discussion on how this calculation is performed. Strategies 1 and 7 are omitted from the figure.

#### Average waiting time per sleep study in the home setting (Dt_Home)

Figure 16 illustrates the effects of varying waiting times for studies in the home setting. Increasing waiting times in the home setting blunts differences across the compared strategies. When the waiting time is 5 weeks, strategies 4,5 and 6 have similar estimated time to diagnosis.

Strategies 1 and 7 are omitted from the figure because they are not meaningful. Strategies 2 and 3 are not affected by this variable with respect to this outcome.

Figure 15 Sensitivity analysis on the average waiting time per sleep study in sleep laboratories: time to final diagnosis in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The “all on CPAP” and “none on CPAP” strategies (1 and 7, respectively) are not shown, because they are not affected by the sensitivity analyses. The number on the right hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

The average waiting time for a sleep study in the lab in strategies 3, 4, and 5 is expected to be 68 percent, 36 percent and 27 percent, respectively, of the waiting time in strategy 2.

Figure 15. Sensitivity analysis on the average waiting time per sleep study in sleep laboratories: time to final diagnosis in a hypothetical cohort of 100,000 participants

Figure 16 Sensitivity analysis on the average waiting time per sleep study in the home setting: time to final diagnosis in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The “all on CPAP” and “none on CPAP” strategies (1 and 7, respectively) are not shown, because they are not affected by the sensitivity analyses. The number on the right hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 16. Sensitivity analysis on the average waiting time per sleep study in the home setting: time to final diagnosis in a hypothetical cohort of 100,000 participants

#### Prevalence (prev)

Figure 17 describes the sensitivity analysis on the prevalence of the condition among referrals. Notably, the mean waiting time decreases with decreasing prevalence in strategy 2. This is because fewer CPAP titration sessions will be performed.

Note that in strategy 4 (screening at home with a portable monitor and then verify positive diagnoses in a split-night study in the lab) the mean time to final diagnosis increases with increasing prevalence. This is because the final diagnosis is set with the split-night study, and the more test positives, the greater the burden on sleep labs and the longer the waiting time for a split-night PSG.

Note that in strategy 5 (screening at home with a portable monitor and then verify negative diagnoses in a split-night study in the lab) the impact of decreasing prevalence is in the opposite direction compared to strategies 2 and 4. In strategy 5, as the prevalence of OSAHS decreases, the number of negative diagnoses with the portable monitors increases, and so does the total number of split-night PSG studies.

Figure 17 Sensitivity analysis on prevalence: time to final diagnosis in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The “all on CPAP” and “none on CPAP” strategies (1 and 7, respectively) are not shown, because they are not affected by the sensitivity analyses. The number on the right hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 17. Sensitivity analysis on prevalence: time to final diagnosis in a hypothetical cohort of 100,000 participants

#### Probability of not showing up for the first PSG or Split-night PSG study

Figure 18 illustrates the corresponding sensitivity analyses. As the probability of no showing up increases, the time to diagnosis decreases in strategies 2 and 3 (because the workload of the sleep labs decreases).

Figure 18 Sensitivity analysis on the probability of not showing up for the first study if it is in the sleep lab: time to final diagnosis in a hypothetical cohort of 100,000 participants

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The “all on CPAP” and “none on CPAP” strategies (1 and 7, respectively) are not shown, because they are not affected by the sensitivity analyses. The number on the right hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 18. Sensitivity analysis on the probability of not showing up for the first study if it is in the sleep lab: time to final diagnosis in a hypothetical cohort of 100,000 participants

#### Other variables

The remaining variables had little impact on the different strategies with respect to this outcome in the prespecified sensitivity analyses. Therefore they are not discussed further. See also the next paragraph.

#### Overview of univariate sensitivity analyses

Figure 19 provides an overview of the univariate sensitivity analyses. The figure summarizes the two variables that have the most profound effect on time to diagnosis in the corresponding strategies in the sensitivity analyses. All other variables have even smaller influence and are not discussed further.

Figure 19 Summary (“tornado” graph) of the variables with the greatest impact on the average time to final diagnosis in the univariate sensitivity analyses

Key: (auto)CPAP: (automated) continuous positive airway pressure titration; C_HomeDx: Specificity of portable monitors; Dt_[Lab | Home]: Mean waiting time for a sleep study in the [lab | home] setting. DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; pNoShow_[PSG | SpNPSG]: probability of no showing up for the first dianostic PSG or the first SpNPSG study; pFail_PSG1: proportion of facility-based PSG that are unsuccessful; prev: prevalence; PSG: polysomnography; pTitr_manCPAP1: probability of technically adequate CPAP titration in the lab; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The “all on CPAP” and “none on CPAP” strategies (1 and 7, respectively) are not shown, because they are not affected by the sensitivity analyses.

The length of each bar represents the change in the outcome for each strategy, when the corresponding variable is varied throughout its whole range in the univariate sensitivity analyses. Only the four more influential variables are shown for each strategy (three for strategy 6, since no other variable had an effect). Because variables are ordered by diminishing influence in each strategy, the image resembles a small tornado, hence the name “tornado” graph.

Figure 19. Summary (“tornado” graph) of the variables with the greatest impact on the average time to final diagnosis in the univariate sensitivity analyses

## Time to CPAP level titration among people with a diagnosis of OSAHS

As discussed in the methods section, this outcome is meaningful only among those who have received a diagnosis of OSAHS.

### Main analyses

Table 12 shows the results of the main analyses, which pertain to a hypothetical cohort of 100,000 middle-aged people. In the two extreme strategies (strategy 1 – “all on CPAP” and strategy 7 – “None on CPAP”) the decision to proceed to CPAP treatment is completely determined; these are not meaningful to analyze further.

Among patients with a positive OSAHS diagnosis, the average time to CPAP titration is approximately 27 weeks when people are managed in the sleep lab at 2 different nights (strategy 2; Table 12). When people are managed with split-night studies the time to a technically adequate CPAP titration study is approximately 10 weeks (strategy 3). In strategies 4,5 and 6 the corresponding time interval is approximately 5 weeks.

Positive OSAHS diagnoses may be either false positive (i.e., person does not have OSAHS) or true positive (i.e., person truly has OSAHS). The time to a technically adequate CPAP titration study is the same for true and false positives. False positive diagnoses would probably not exhibit improvement in their AHI with CPAP treatment or would probably not tolerate the treatment as well; however, these subsequent events are not part of our analysis.

Table 12 Baseline analyses: time to CPAP in a hypothetical cohort of 100,000 middle-aged people suspected of OSAHS

Strategy (for diagnosis and CPAP titration) | Proportion offered CPAP (%) | Mean time to CPAP^*^ (among those offered CPAP) [weeks]
1. None started on CPAP | 0 | NA^a^
2. Full night PSG, treatment PSG | 54 | 27.3
3. Split-night PSG | 51 | 9.8
4. Home diagnosis, split-night PSG to verify positive cases | 44 | 5.0
5. Home diagnosis, split-night PSG in all negative cases | 62 | 6.2
6. Home diagnosis, home CPAP titration | 56 | 4.8
7. All started on CPAP | 100 | NA^a^

CPAP: continuous positive airway pressure; OSAHS: Obstructive sleep apnea-hypopnea syndrome (see methods for definition).

* “Time to CPAP” means time to a technically adequate CPAP titration study. The mean time is the same or people who have OSAHS and people who do not have OSAHS.

a Not meaningful to assess

### Analyses among older adults

Table 13 shows results for a hypothetical cohort of 100,000 70 year old people. Among people who received a positive diagnosis of OSAHS the time to a technically adequate CPAP titration study is similar to that calculated among middle-aged adults. The same caveats apply here as well.

Table 13 Baseline analyses: time to CPAP in a hypothetical cohort of 100,000 older adults suspected of OSAHS

Strategy (for diagnosis and CPAP titration) | Proportion offered CPAP (%) | Mean time to CPAP^*^ (among those offered CPAP) [weeks]
1. None started on CPAP | 0 | NA^a^
2. Full night PSG, treatment PSG | 27 | 22.5
3. Split-night PSG | 28 | 9.9
4. Home diagnosis, split-night PSG to verify positive cases | 23 | 3.9
5. Home diagnosis, split-night PSG in all negative cases | 52 | 7.2
6. Home diagnosis, home CPAP titration | 46 | 4.8
7. All started on CPAP | 100 | NA^a^

CPAP: continuous positive airway pressure; NA: Not applicable; OSAHS: Obstructive sleep apnea-hypopnea syndrome (see methods for definition). Older adults are Medicare beneficiaries aged 70 years old.

* “Time to CPAP” means time to a technically adequate CPAP titration study. The mean time is the same or people who have OSAHS and people who do not have OSAHS.

a Not meaningful to assess

### Sensitivity analyses

We conducted wide range sensitivity analyses to assess the robustness of the findings. Here, we present the results of univariate analyses for the variable that had some influence on the average time to technically adequate CPAP initiation study among people who were offered CPAP (i.e., those with either true positive or false positive diagnoses). The corresponding analyses with respect to the whole cohort are not readily interpretable.

#### Average waiting time per sleep study in the lab setting (Dt_Lab)

Figure 20 and Table 14 show the pertinent analyses. On interpreting this figure on must bear in mind that the corresponding average waiting times depend on the total workload of the sleep labs. In these univariate analyses the corresponding waiting times in strategies 3, 4 and 5 are 68 percent, 36 percent and 27 percent of those in strategy 2. Please, refer to Appendix B for a discussion of how the mean waiting times in strategies 3, 4 and 5 are calculated based on the mean waiting time set for strategy 2.

In strategy 2 at least two sessions in the lab will be needed for people who have positive diagnoses and will be offered CPAP. In strategy 3 (management in the lab with split night studies) the dependency is relatively smaller because of the smaller burden that is placed on sleep labs, and because in the majority of people diagnosis and CPAP level titration is performed in a single session.

Figure 20 Sensitivity analysis on the average waiting time per sleep study in the lab setting: Average time to CPAP level titration among those who are offered CPAP

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The “all on CPAP” and “none on CPAP” strategies (1 and 7, respectively) are not shown, because they are not affected by the sensitivity analyses. The number on the right hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

The average waiting time for a sleep study in the lab in strategies 3, 4, and 5 is expected to be 68 percent, 36 percent and 27 percent, respectively, of the waiting time in strategy 2.

Figure 20. Sensitivity analysis on the average waiting time per sleep study in the lab setting: Average time to CPAP level titration among those who are offered CPAP

Table 14 Sensitivity analysis in average waiting time for a sleep study in strategy 2 (DxPSG, TxPSG): Average time to CPAP in a hypothetical cohort of 100,000 middle-aged people suspected of OSAHS

Strategy (for diagnosis and CPAP titration) | Proportion offered CPAP (%) | Mean time to CPAP assuming different average waiting times for a sleep study^*^ (among those offered CPAP) [weeks]
Strategy (for diagnosis and CPAP titration) | Proportion offered CPAP (%) | 4.0^a^ | 8.5^a^ | 13.0^a,b^ | 17.5^a^ | 22.0^a^
1. None started on CPAP | 0 | NA^c^ | NA^c^ | NA^c^ | NA^c^ | NA^c^
2. Full night PSG, treatment PSG | 54 | 8.4 | 17.8 | 27.3 | 36.7 | 46.1
3. Split-night PSG | 51 | 3.0 | 6.4 | 9.8 | 13.2 | 16.2
4. Home diagnosis, split-night PSG to verify positive cases | 44 | 3.1 | 4.1 | 5.0 | 6.0 | 7.0
5. Home diagnosis, split-night PSG in all negative cases | 62 | 4.9 | 5.5 | 6.2 | 6.6 | 7.2
6. Home diagnosis, home CPAP titration | 56 | 4.8 | 4.8 | 4.8 | 4.8 | 4.8
7. All started on CPAP | 100 | NA^c^ | NA^c^ | NA^c^ | NA^c^ | NA^c^

CPAP: continuous positive airway pressure; NA: Not applicable; OSAHS: Obstructive sleep apnea-hypopnea syndrome (see methods for definition). Older adults are Medicare beneficiaries aged 70 years old.

* “Time to CPAP” means time to a technically adequate CPAP titration study. The mean time is the same or people who have OSAHS and people who do not have OSAHS.

a Average waiting time for a sleep study in the lab in strategy 2; the waiting times for lab studies in the other strategies are adjusted accordingly, as shown in Appendix B.

b Value in baseline analysis

c Not meaningful to assess

#### Average waiting time for a sleep study in the home setting (Dt_Home)

Figure 21 shows the corresponding sensitivity analysis. Strategies that incorporate studies in the home setting (strategies 4, 5 and 6) are affected by this quantity. Note that if the mean delay is more than three weeks, management at home (strategy 6) yields similar time delays with management in the labs with split-night studies.

Figure 21 Sensitivity analysis on average waiting time for a sleep study at home: time until successful CPAP titration

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The “all on CPAP” and “none on CPAP” strategies (1 and 7, respectively) are not shown, because they are not affected by the sensitivity analyses. The number on the left hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 21. Sensitivity analysis on average waiting time for a sleep study at home: time until successful CPAP titration

#### Prevalence (prev)

Figure 22 illustrates the impact of prevalence. As noted above, in these analyses we focus only on patients who were offered CPAP, and not to the whole cohort. However, the prevalence of OSAHS affects the number of positive diagnoses, and therefore the number of people who will undertake CPAP titration studies. This in turn impacts on the workload of the sleep labs and the average waiting time per sleep study in the lab setting.

Strategy 3 (management with split-night studies) is unaffected by this sensitivity analysis, because diagnosis and CPAP titration (if needed) take place in a single night. Strategy 6 (management outside the sleep lab) is also unaffected, because the average waiting time for a sleep study in the home setting is assumed to be independent of the total number of sleep studies performed.

Note that in strategy 5 (screening at home with a portable monitor and then verify negative diagnoses in a split-night study in the lab) the impact of decreasing prevalence is in the opposite direction compared to strategy 4. In strategy 5, as the prevalence of OSAHS decreases, the number of negative diagnoses with the portable monitors increases, and so does the total number of split-night PSG studies.

Figure 22 Sensitivity analysis on prevalence: Average time to successful CPAP level titration among those who are offered CPAP

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The “all on CPAP” and “none on CPAP” strategies (1 and 7, respectively) are not shown, because they are not affected by the sensitivity analyses. The number on the left hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 22. Sensitivity analysis on prevalence: Average time to successful CPAP level titration among those who are offered CPAP

#### Probability of not showing up for the first PSG or Split-night PSG study

Figure 23 illustrates the corresponding sensitivity analyses. As the probability of no showing up increases, the time to a technically adequate CPAP study in strategies 2 and 3 decreases (because the workload of the sleep labs decreases).

Figure 23 Sensitivity analysis on the probability of not showing up for the first study if it is in the sleep lab: Average time to successful CPAP level titration among those who are offered CPAP

Key: (auto)CPAP: (automated) Continuous positive airway pressure titration; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; OSAHS: obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP levels in the sleep laboratory.

The “all on CPAP” and “none on CPAP” strategies (1 and 7, respectively) are not shown, because they are not affected by the sensitivity analyses. The number on the left hand side of each line in the graph corresponds to the number of the modeled strategy (see text). The vertical dashed line shows the prevalence that was used in the baseline analyses.

Figure 23. Sensitivity analysis on the probability of not showing up for the first study if it is in the sleep lab: Average time to successful CPAP level titration among those who are offered CPAP

#### Other variables

The remaining variables had little impact on the different strategies with respect to this outcome in the prespecified sensitivity analyses. Therefore they are not discussed further. See also the next paragraph.

#### Overview of univariate sensitivity analyses

Figure 24 provides an overview of the univariate sensitivity analyses. The figure summarizes the four variables that have the most profound effect on time spent in “high-risk” health states in the corresponding strategies in the sensitivity analyses. All other variables have even smaller influence and are not discussed further.

Figure 24 Summary (“tornado” graph) of the variables with the greatest impact on the average to CPAP in the univariate sensitivity analyses (among people offered CPAP)

Key: (auto)CPAP: (automated) continuous positive airway pressure titration; C_HomeDx: specificity of home diagnosis with portable monitors; DxPSG: diagnostic polysomnography in the sleep laboratory; HomeDx: home diagnosis; Dt_Lab: average waiting time for a sleep study in the lab setting; OSAHS: obstructive sleep apnea-hypopnea syndrome; pFail_[PSG1 | SpNSPG1 | HomeDx1]: proportion of [facility-based PSG | split-night PSG | home ] studies that are technically inadequate; pNoShow_[PSG | SpNPSG]: probability of not showing up for the first study when it is in the sleep lab. prev: prevalence; PSG: polysomnography; pTreatInconcl: probability to start on CPAP if pressure level titration is technically inadequate, but a positive diagnosis of OSAHS exists; SpNPSG: split-night polysomnography; TxPSG: titration of CPAP level in the sleep laboratory.

The “all on CPAP” and “none on CPAP” strategies (1 and 7, respectively) are not shown, because they are not affected by the sensitivity analyses.

The length of each bar represents the change in the outcome for each strategy, when the corresponding variable is varied throughout its whole range in the univariate sensitivity analyses. Only the four more influential variables are shown for each strategy. Because variables are ordered by diminishing influence in each strategy, the image resembles a small tornado, hence the name “tornado” graph.

Figure 24. Summary (“tornado” graph) of the variables with the greatest impact on the average to CPAP in the univariate sensitivity analyses (among people offered CPAP)