# Methods

The analyses use Markov processes to simulate 7 different strategies. The transition probabilities used in the models are based on estimates derived from our own systematic reviews of the literature, from other systematic reviews that were updated with focused literature searches, from individual papers, or using assumptions that were considered reasonable. When applicable, meta-analysis was used to summarize estimates from a collection of relevant studies. More details are given in the following sections. As of this writing, there are ongoing randomized trials that are expected to provide useful data on the role of portable monitors compared to facility-based PSG. However, their results are not available yet and could not be used to inform the modeling.

This analysis is performed from the perspective of the institutions that conduct sleep studies and extends up to a time-horizon of 2 years or until they had a technically adequate CPAP titration study. The modeled populations, strategies and the outcomes we assessed are reported in the corresponding following sections.

## Definitions and terminology

### Operational definition of OSAHS

We defined OSAHS as AHI of at least 15 events/hour in facility-based PSG, among people who are referred for further study on the basis of suggestive symptoms and signs.

Most clinicians consider that the cutoff of 15 events/hour of sleep in facility-based PSG is indicative of (at least moderately severe) OSAHS.

### Middle-aged and older adults

As discussed later in this section, for many transition probabilities in the mathematical models, available data pertained to middle aged people without significant comorbidities. Because data on older people were not available, we made several assumptions on the values of several probabilities in this population. Thus, different analyses were performed for hypothetical cohorts of middle-aged 50-year old people and for older adults, namely 70 years of age.

- Middle-aged adults are men and women who are 50 years old (on average). The vast majority of the available studies focuses on people with average age around 50 to 52 years.
- Older adults or Medicare beneficiaries are men and women who are (on average) 70 years old. Identifying older adults with Medicare beneficiaries is not accurate, because some of the latter are younger than 65 years old (e.g., those with disabilities). However, most Medicare beneficiaries are over 65 years of age, and this simplification is not misleading.

### Facility-based PSG and split-night studies

- The terms diagnostic facility-based and diagnostic laboratory-based PSG are used interchangeably throughout this report. They refer to the comprehensive sleep study that is performed in specialized institutions for the diagnosis of OSAHS, lasts a whole night, and is based on the collection of a complete set of neurophysiologic and respiratory data.
- Facility-based PSG for CPAP level titration is a whole night study in a specialized sleep clinic or laboratory, to determine the optimal pressure level. This happens on a different night from the diagnostic facility-based PSG.
- Split-night studies are sleep studies that are performed in the specialized sleep laboratory or clinic, and combine the diagnostic part and the titration of CPAP (if CPAP is needed) during the same night. The first half of the night study is reserved for diagnosis of OSAHS; if needed, the second part of the study is reserved for titration of CPAP level.

### Titration of CPAP level

- A technically adequate CPAP titration study is a study that was completed, irrespective of its findings. Fore example, depending on whether the studied person has OSAHS or not, a technically adequate titration study is assumed to:
  - Decide which CPAP (pressure) level reverses sleep disturbances, provided that a person has OSAHS
  - Was unable to provide a CPAP pressure level the reverses sleep disturbances, because a person does not have OSAHS.
- A technically inadequate CPAP titration study might have ended prematurely (e.g., if the person did not sleep at all during the study, secondary to equipment failure) and cannot reach any conclusion. We assume that a technically inadequate study will have to be repeated to allow for any meaningful conclusion.
- An autotitration home study is the use of an auto-titrating CPAP machine to perform pressure level titration. It is assumed that each attempt to auto-titrate is short-term triage of auto-titrating CPAP devices, just to obtain an optimal pressure level.

### Apnea-Hypopnea Index (AHI) and Respiratory Disturbance Index (RDI)

The frequency of respiratory events during sleep can be used to quantify the severity of OSAHS.

frequency of respiratory events = (N_respiratory events_)/(Total sleep time)

The majority of the published studies define two metrics for the frequency of the respiratory events, namely the apnea-hypopnea index and a “respiratory disturbance index”. We caution that the latter, as defined in the published studies, is not the respiratory disturbance index as used in everyday clinical practice by sleep physicians, but a proxy of the former (see below for detailed explanation). Other indices have also been used.

- Apnea-Hypopnea Index (AHI). The number of apneas and hypopneas per hour of sleep. It is a fraction, where the numerator is the number of apneas and hypopneas, and the denominator is total sleep time.
- Respiratory Disturbance Index (RDI). As mentioned above, studies of portable monitors do not define RDI in the same way it is defined in everyday clinical practice in the sleep laboratory (i.e., the quotient of the total number of RERAs, apneas and hypopneas divided by total sleep time). In studies of portable monitors RDI is a quantity that approximates AHI, whenever the numerator (apneas or hypopneas) or the denominator (total sleep time) or both are not measured directly. In most cases the denominator is the total recording time instead of the total sleep time. Proxies for the numerator vary depending on the recorded signals and their assessment. Therefore exact definition of RDI may vary across different studies of portable monitors.

### Types of monitors used in sleep studies

The American Sleep Disorders Association (ASDA – now named American Academy of Sleep Medicine) classified the different monitors that have been used in sleep studies into four categories, depending on which channels they record and evaluate.23 This classification scheme is rather dated; newer monitors have been developed that evaluate signals not considered in the original ASDA classification. Such monitors would be classified as category IV in the original classification scheme. To account for newer monitors we modified the ASDA classification, by splitting category IV into two subgroups: monitors assessing three or more bioparameters (where the newer monitors would fall) and monitors assessing one or two bioparameters (original category for type IV).

More details on the classification of sleep monitors and a discussion on how newer devices may fit in this classification scheme are provided in our Technology Assessment “Home diagnosis of obstructive sleep apnea-hypopnea syndrome” Section A3.

Here, we used the operational rules described in Table 1 to classify sleep monitors. Very similar rules have been applied in previous systematic reviews.14 Briefly:

- Type I is facility-based PSG.
- Type II monitors record the same information as type I (perhaps with fewer channels). Type II monitors record signals that allow the reliable identification of (micro)arousals from sleep (e.g. EOG, chin EMG, EEG – see Table 1 footnote for abbreviations) and at least two respiratory channels (two airflow channels or one airflow and one effort channel).
- Type III monitors do not record the channels that differentiate between sleep and wake, but have at least two respiratory channels (two airflow channels or one airflow and one effort channel).
- Type IV are all other monitors that fail to fulfill criteria for type III monitors. These are split into two subgroups: those assessing three or more bioparameters (i.e., most newer monitors fall here) and those assessing one or two bioparameters (i.e, the original ASDA level IV category).

We classified each monitor according to the channels that were actually used in the pertinent study. For example, if not all channels of a nominally type III monitor were used or analyzed, we classified the monitor as “type IV” for the particular study. This “downlabeling” occurred rarely (see the previous Technology Assessment for more details).

Table 1 Delineation of operational rules used to classify monitors in sleep studies

Type or Level | Portability | Indicative N_channels_ | Indicative signals | ≥2 airflow /effort channels | Identifies sleep /wake | AHI
I | Facility-based | ~14–16 | EEG, EOG, EMG, ECG/HR, airflow, effort, SaO_2_ | Yes | Yes | Yes
II | Portable | ≥7 | (may have EEG), HR^*^, EOG, chin EMG, ECG/HR, airflow, effort, SaO_2_ | Yes | Yes | Yes
III | Portable | ≥4 | Airflow and/or effort, ECG/HR, SaO_2_ | Yes | No | No
IV_3+_ | Portable | ≥3^**^ | Airflow, HR, peripheral arterial tonometry, SaO_2_ | No | No^***^ | No^***^
IV_2−_ | Portable | ~1–2 | [All monitors not qualifying for type III] | No | No | No

AHI: Apnea-Hypopnea index; ECG: electrocardiogram; EEG: Electroencephalogram; EMG: electromyography; EOG: Electro-oculogram; HR: heart rate; SaO_2_ arterial O_2_ saturation;

* Heart rate is allowed instead of EEG in type II monitors. Essentially, many type II monitors gather the same signals as type I monitors.

** Criteria for type III are not met

*** May include monitors that measure signals that are in principle able to identify arousals from sleep (are good surrogates for arousals).

In the modeling strategies we will assume that a prototype portable monitor is being used in the home setting in the corresponding strategies, rather than a specific brand. The prototype monitor has diagnostic abilities similar to those of type III devices, or type IV devices that assess at least 3 bioparameters (see below).

## Search Strategy

We conducted comprehensive searches in MEDLINE from its inception through the 28^th^ of February 2007 to identify English language publications that described prospective studies comparing portable monitors with facility-based PSG, or describing adverse events or complications of sleep studies. Three electronic searches were performed at different time points. The three searches were incremental (i.e., the latest search included all the citations of the previous searches). Relevant systematic reviews and meta-analyses, consensus statements and recommendations were also identified. Various search terms were used, including terms that described sleep studies with different monitors, OSAHS, and continuous positive airway pressure (CPAP) treatment for OSAHS. The complete search strategy has been reported in detail in Appendix A of the Tufts-NEMC technology assessment “Home diagnosis of obstructive sleep apnea-hypopnea syndrome”. Reference lists from relevant systematic or non-systematic reviews, the reviewed studies, and publications on practice recommendations were also examined for potentially useful additional citations.

## Markov processes

The current problem is especially amenable to mathematical modeling: There are no studies that directly compared multiple strategies for the diagnosis of OSAHS and CPAP level titration. Markov modeling is an established and widely used analytic methodology. It is used in decision analyses to try to more accurately represent complex processes that involve transitions between different “health states” (complex transitions are not handled easily with simple decision trees).31,32

### A simple example of a Markov model

For simplicity, assume that we want to model a hypothetical cohort of patients and that we are interested in the proportion of patients who are well, become sick or die. We can use a Markov model with three “health states”, namely being “well”, being “sick” and being “dead”. We assume that as time passes:

1. people who are “well”
  a. may become “sick”
  b. may die before becoming “sick”
2. people who are “sick”
  a. may become “well” (i.e., the disease is curable)
  b. may die
3. people who are “dead” always remain dead.

Each of the aforementioned transitions happens with a predefined probability (transition probability).

Time in Markov processes ismodeled in discrete intervals, i.e., it progresses in steps, or time cycles (e.g., one month long time-cycles). In the beginning of the simulation, all people are assumed to be “well”. At the end of each time-cycle we calculate the proportion of people who find themselves in each of the three health states (“well”, “sick”, and “dead”) using the transition probabilities. At each time point each patient/ member of the hypothetical cohort is allowed to be in a single health state.

An intuitive introduction to Markov models for the interested reader is found in several textbooks, manuscripts and on the web.31–34

### Implementation

The different strategies for the diagnosis of OSAHS and the initiation of CPAP treatment were simulated with mathematical models (Markov processes) using the DATA software package (DATA ver 2.6.7; TreeAge Software Inc, Boston, Massachusetts). Each process simulates a hypothetical cohort of 100,000 people who are suspected of OSAHS, presumably on the basis of suggestive symptoms and signs. The cohorts are followed prospectively for 2 years or until all people have been diagnosed and have had a technically adequate CPAP titration study (when applicable).

Time in Markov processes is measured in discrete 1 week “cycles”. As mentioned above, each strategy is modeled as a web of mutually exclusive (and exhaustive) health states with a combination of given characteristics, so that a person is allowed to be in a single health state at any given time cycle. At the end of each cycle people may remain in the same health state or transit to other prespecified health states with predefined probabilities for each transition. The whole process is repeated at the end of the next cycle, and the software calculates the proportion of people in the cohorts who find themselves in each health state at the end of each cycle (cohort analysis method).

The modeled strategies and the values of the transition probabilities are described in the following sections.

## Simulated populations

We simulated 2 different populations: People who are middle-aged (~50 years old) and people who are older adults (~70 years old). The second population is of particular interest, but the literature does not provide data on needed transition probabilities among older adults. We therefore based our analyses on extrapolations from transition probabilities among middle-aged people. More specifically:

All eligible studies enrolled people who were predominantly men, obese (average BMI above 27 kg/m^2^ in almost all studies), and with average age approximately 50 years old. The typical enrollee did not have comorbidities that may affect sleep (these were excluded upfront in almost all studies). In most studies people were referred to sleep labs on the basis of suggestive symptoms (i.e., fatigability, day somnolence; – see also under “Prevalence” under “Probabilities used in the simulations”).

Based on the above, one analysis simulates a cohort similar to the enrollees of the diagnostic studies, that is middle-aged people (age 50 years) without significant comorbidities who have suggestive symptoms and signs.

A second analysis (essentially a sensitivity analysis scenario) simulated a cohort for older adults (i.e., age 70 years on average – to approximate the majority of the Medicare beneficiaries). An additional factor that is being considered when deriving the transition probabilities in this secondary analysis is the potential for “indication creep”. Indication creep would emerge when testing for sleep apnea becomes easy and accessible to the point that people at low (or very low) risk for OSAHS receive testing. Explicit assumptions for the cohort on 70 year old people are made in the “Probabilities used in the simulations” section.

## Data abstraction

Data were abstracted by a single reviewer (TT) directly into the corresponding summary tables. When needed, specialized planimetric software (Engauge Digitizer ver. 2.14; Mark Mitchell, 2002) was used to digitize figures and extract numerical information with the best allowable accuracy. Details are given in the corresponding sections that describe each individual transition probability.

## Description of the modeled strategies

### Brief descriptions and global assumptions

Seven different strategies were modeled (outlined in Table 2). The following is a brief description. Diagrams of the strategies and more detailed descriptions are provided in the next section.

- Strategy 1 (“None on CPAP). None in the hypothetical cohort will ever be tested for OSAHS or offered CPAP treatment. This is one extreme scenario that has been included for comparison.
- Strategy 2 (“DxPSG, TxPSG”). All people in the hypothetical cohort will receive a diagnostic session (DxPSG) in the sleep laboratory. If the exam is positive, a second session for CPAP level titration will be scheduled.
- Strategy 3 (“Split-Night PSG”). All people in the hypothetical cohort will be assessed with split-night studies. If the first half of the exam is positive, the second half is used to titrate the CPAP level. If the first half of the exam is negative no CPAP titration is attempted.
- Strategy 4 (“HomeDx, SpNPSG(+)”). All people in the hypothetical cohort will be assessed in the home setting with portable sleep monitors (HomeDx). Those with positive diagnoses (indexed by the “+” sign in the name of the strategy) will be subjected to split-night studies in the sleep laboratory, to verify the diagnosis and to titrate CPAP level (if applicable). This is a combination of strategies 3 and 6 (see below).
- Strategy 5 (“HomeDx, SpNPSG(−)”). This is similar to Strategy 4 in structure, but here people with positive diagnoses in the home setting are offered CPAP level titration, and people with negative diagnoses in the home setting will be re-evaluated with split-night studies in the lab (to minimize the number of people with OSAHS who have been missed as false negatives).
- Strategy 6 (“HomeDx, autoCPAP”). The whole hypothetical cohort is managed entirely outside the sleep laboratory. Portable monitoring in the home setting (“HomeDx”) is used for the diagnosis, and auto-titration of CPAP is attempted again in the home setting on a different night.
- Strategy 7 (“All on CPAP”). The whole cohort will be offered CPAP treatment (with auto-titration or empirical titration of the pressure level). In this scenario none is tested for OSAHS. This is the other extreme scenario that has been included for comparison.

Table 2 Outline of the seven modeled strategies

Strategy Number (Name) | Diagnosis | CPAP level titration | N of sleep studies
1 (None on CPAP) | [None] | [None on CPAP] | 0
2 (DxPSG, TxPSG) | Lab-PSG | Lab-PSG | ≥2
3 (Split-Night PSG) | Split-night PSG | | ≥1
4 (HomeDx, SpNPSG(+)) | Home PM | - Split-night PSG (if positive Home PM); - No further action (if negative Home PM) | ≥2
5 (HomeDx, SpNPSG(−)) | Home PM | - Home autoCPAP (if positive Home PM); - Split-night PSG (if negative Home PM) | ≥1
6 (HomeDx, autoCPAP) | Home PM | Home autoCPAP | ≥2
7 (All on CPAP) | [None] | [All start on CPAP] | 0

CPAP: Continuous Positive Airway Pressure; N: number; PM: portable monitor; PSG: polysomnography

#### Global assumptions

The following assumptions are used for all strategies:

1. The severity of obstructive sleep apnea would be stable for each patient over the whole time-period of the assessment.
2. The risk of death over the whole time period of the assessment is negligible. In reality, the annual mortality rate is not zero (both for middle-aged people and especially so for Medicare beneficiaries). Moreover, there is evidence suggesting an association of OSAHS with increased risk of death from motor vehicle accidents, and perhaps increased risk for heart disease and stroke. Notwithstanding these caveats, we decided not to model mortality outcomes, because we focus on the diagnosis of the condition rather than long term projections.
3. Co-morbidities and co-existing disorders, or health conditions other than OSAHS that may affect sleep are not explicitly modeled.
4. Sleep lab capacity is assumed fixed throughout the simulation, i.e., the sleep labs do not expand their capacity during the follow up. A fixed sleep lab capacity implies that a smaller volume of sleep studies would result in shorter average waiting times.

In addition, the following implicit assumptions are made:

1. Benefits of treatments will be assumed by those with true positive diagnoses
2. Avoidance of unnecessary treatments to those with true negative diagnoses
3. Potential harm and unnecessary costs to those with false positive or false negative diagnoses

### Detailed descriptions and strategy-specific assumptions

It is meaningful to discuss in more detail only strategies 2 to 6; the extreme strategies 1 and 7 are included for comparison and their results are invariable in all sensitivity analyses.

Appendix A gives a full description of the modeled strategies, by providing the actual model architecture and the conditional probabilities for each transition between the various health states.

#### Strategy 2: Management with facility-based PSG (DxPSG, TxPSG)

Figure 1 illustrates strategy 2. People suspected of OSAHS will be subjected to facility-based PSG for diagnosis. Those with negative diagnosis are not offered a CPAP titration study. Those with positive diagnosis will be scheduled for a second session in the sleep laboratory in order to titrate CPAP level. If the diagnostic PSG study is unsuccessful it may be repeated (up to two times). People with all three PSG studies unsuccessful are considered without OSAHS and are not offered a CPAP titration study. In the simulations this is a negligible proportion.

For people with positive diagnosis, the next step is a study to titrate CPAP level. Up to 3 sessions for CPAP level titration are allowed (in case of technically inadequate titration study).

If the third session for CPAP level titration is technically inadequate, the main analyses assume that the patient (who already has a positive diagnosis) will be offered CPAP treatment (e.g., with empirical level titration). An alternative scenario assumes that these patients would not be offered CPAP, perhaps because they do not tolerate the treatment.

The sleep laboratories have a given capacity (e.g., total number of sleep beds) that allows a certain number of sleep studies to be performed each week. Therefore, there is an average delay before each sleep study.

Figure 1 Layout of the distinct health states assumed by strategy 2 (facility-based PSG)

CPAP: continuous positive airway pressure; repeat; repeating of a technically inadequate diagnostic PSG or a failed CPAP level titration study; test(+/−/tech inadeq): positive/negative/inconclusive test (technically inadequate) result; titration (tech adeq/tech inadeq):technically adequate/inadequate CPAP level titration.

* In sensitivity analyses we assumed that this branch is not offered CPAP (see text).

We represent the model using a tree structure to enhance clarity. The actual Markov process is described in Appendix A.

Strategy 2 assumes management in the sleep lab in at least two different nights. The first night is to set the diagnosis of OSAHS. The second night is to titrate the level of CPAP pressure for people who have a positive diagnosis. Because of assumed finite sleep lab capacity, a time delay is assumed. People with a positive test result will proceed to CPAP level titration during the coming week. Those with a negative test will not be offered CPAP. Those with an inconclusive test will repeat the diagnostic study up to two times. Similar for people with technically inadequate CPAP level titration.

Figure 1. Layout of the distinct health states assumed by strategy 2 (facility-based PSG )

#### Strategy 3: Management with split-night studies (SpNPSG)

Figure 2 illustrates the different health states modeled in strategy 3. People suspected of OSAHS are evaluated in the sleep laboratory with split-night studies. Because all sleep studies are performed in the sleep lab, there is a time delay before each sleep examination. All people with negative diagnosis are not offered CPAP. People with positive diagnosis in the first part of the split-night study will be subjected to a CPAP titration study.

Technically inadequate split-night studies are repeated. Moreover, we assume that only the needed part of a split night study would be repeated (i.e., the CPAP titration part only if the diagnostic part was technically adequate).

A person may receive up to 4 split-night studies in the sleep laboratory if needed, i.e., if the previous split-night studies are technically inadequate (i.e., when either one of the their two parts is technically inadequate). In the simulations, the proportion of people who have more than one technically inadequate studies is very small. If all four split-night studies are unsuccessful, people are not started on CPAP. In the simulations this is a negligible proportion.

Figure 2 Layout of the distinct health states assumed by strategy 3 (Split-Night PSG)

CPAP: continuous positive airway pressure; repeat; repeating of a technically inadequate split-night session; test(+/−/tech inadeq): positive/negative/technically inadequate test result; titration (tech adeq/tech inadeq): technically adequate/inadequate CPAP level titration.

We represent the model using a tree structure to enhance clarity. The actual Markov process is described in Appendix A.

Strategy 3 assumes management in the sleep lab in a single session using split-night studies. Because of assumed finite sleep lab capacity, not all people receive the split-night study immediately (i.e., a time delay is assumed). People with a positive test result and successful titration will be offered CPAP. Those with an technically inadequate diagnosis or titration will repeat the split night study up to three times.

Figure 2. Layout of the distinct health states assumed by strategy 3 (Split-Night PSG)

#### Strategy 4: Diagnosis with portable monitors in the home setting, and management of positive cases with facility-based PSG (HomeDx, SpN PSG(+))

Figure 3 illustrates the different health states modeled in strategy 4. This strategy is a combination of strategy 3 and strategy 5 (see below). People suspected of OSAHS are screened in the home setting using portable sleep monitors. All positive diagnoses are then referred to the sleep laboratory for split-night studies. All negative diagnoses are not considered for CPAP.

The positive diagnoses in the home setting will be verified during the first sleep study. For some people the first split-night study will be negative (i.e., will not verify the home diagnosis); these will not be offered CPAP.

The sleep laboratories have a given capacity that allows a certain number of sleep studies to be performed each week. Therefore, time delays are assumed before each split-night PSG.

In reality, split-night studies may be technically inadequate because they have a technically inadequate diagnostic part, or a technically inadequate CPAP level titration part. In this strategy it is assumed that the diagnostic part of the first split-night study is always technically adequate. This is a reasonable assumption given that patients who reach the health state of the first split-night study have already been diagnosed with OSAHS using the portable monitors.

If CPAP level titration is unsuccessful in the third (and last allowed) split-night study, the main analyses assume that the patient will be offered CPAP (e.g., with empirical level titration). An alternative scenario assumes that these patients would not be offered CPAP, perhaps because they do not tolerate it.

Figure 3 Layout of the distinct health states assumed by strategy 4 (screening at home with portable monitors, and Split-Night PSG for positive cases)

CPAP: continuous positive airway pressure; repeat; repeating of a technically inadequate diagnostic PSG or a failed CPAP level titration study; test(+/−/tech inadeq): positive/negative/technically inadequate test result; titration (tech adeq/tech inadeq): technically adequate/inadequate CPAP level titration.

* In sensitivity analyses we assumed that this branch is not offered CPAP (see text).

We represent the model using a tree structure to enhance clarity. The actual Markov process is described in Appendix A.

Strategy 4 assumes diagnosis at home (after a small time delay) and then, in a separate session, verification of the diagnosis and titration of the CPAP level with a split night study in the lab. Because of assumed finite sleep lab capacity, not all people will receive split-night studies immediately after a positive home test (i.e., there is a time delay).

Figure 3. Layout of the distinct health states assumed by strategy 4 (screening at home with portable monitors, and Split-Night PSG for positive cases)

#### Strategy 5: Diagnosis with portable monitors in the home setting; positive cases receive home CPAP auto-titration, while negative cases are re-evaluated with facility-based split-night studies (HomeDx, SpN PSG(−))

Figure 4 illustrates the different health states modeled in strategy 5. This strategy resembles Strategy 4 in structure, but is quite different. People suspected of OSAHS are screened in the home setting using portable sleep monitors. All positive diagnoses are offered auto-titration of CPAP levels at home (so that there is as little delay as possible in proceeding to treatment). To minimize false negatives, all negative cases are referred to the sleep laboratory for split-night studies. In more detail:

Positive diagnoses at home: All these patients will be offered auto-titration of CPAP levels at home. Up to three sessions for auto-titration of CPAP are allowed (in case of technically inadequate sessions). If CPAP level titration is technically inadequate in the third (and last allowed) session, the main analyses assume that the patient (who already has a positive diagnosis) will be offered CPAP (e.g., with empirical level titration). An alternative scenario assumes that these patients would not be offered CPAP, perhaps because they do not tolerate it.

Negative diagnoses at home: All these patients are re-evaluated with split-night studies. The sleep laboratories have a given capacity that allows a certain number of sleep studies to be performed each week. Therefore, time delays are assumed before each split-night PSG.

In reality, split-night studies may be technically inadequate because they have a technically inadequate diagnostic part, or a technically inadequate CPAP level titration part. In this strategy it is assumed that the diagnostic part of the first split-night study is always technically adequate. This is a reasonable assumption given that patients who reach the health state of the first split-night study have already been diagnosed with OSAHS using the portable monitors.

If CPAP level titration is unsuccessful in the third (and last allowed) split-night study, the main analyses assume that the patient will be offered CPAP (e.g., with empirical level titration). An alternative scenario assumes that these patients would not be offered CPAP, perhaps because they do not tolerate it.

Figure 4 Layout of the distinct health states assumed by strategy 5 (screening at home with portable monitors; auto-titration of CPAP at home for positive cases and re-evaluation of negative cases with Split-Night PSG)

CPAP: continuous positive airway pressure; repeat; repeating of a technically inadequate diagnostic PSG or a failed CPAP level titration study; test(+/−/tech inadeq): positive/negative/technically inadequate test result; titration (tech adeq/tech inadeq): technically adequate/inadequate CPAP level titration.

* In sensitivity analyses we assumed that this branch is not offered CPAP (see text).

We represent the model using a tree structure to enhance clarity. The actual Markov process is described in Appendix A.

Strategy 5 assumes diagnosis at home (after a small time delay). People with positive diagnosis are offered auto-titration of CPAP at home (separate session in a different night). People with negative diagnoses are re-evaluated with split-night studies, to reduce the number of false negatives. Because of assumed finite sleep lab capacity, not all people will receive split-night studies immediately after a positive home test (i.e., there is a time delay).

Figure 4. Layout of the distinct health states assumed by strategy 5 (screening at home with portable monitors; auto-titration of CPAP at home for positive cases and re-evaluation of negative cases with Split-Night PSG)

#### Strategy 6: Management outside the sleep laboratories (HomeDx, autoCPAP)

Figure 5 illustrates the different health states modeled in strategy 5. All people suspected of OSAHS are screened in the home setting using portable sleep monitors. All positive diagnoses are then offered auto-titration of CPAP levels at home. If a home-based study is technically inadequate, it may be repeated up to two times. People who have all three diagnostic studies technically inadequate are assumed not to start on CPAP. In the simulations this proportion is very low.

Similarly, up to three sessions for auto-titration of CPAP are allowed (in case of technically inadequate sessions). If CPAP level titration is technically inadequate in the third (and last allowed) session, the main analyses assume that the patient (who already has a positive diagnosis) will be offered CPAP (e.g., with empirical level titration). An alternative scenario assumes that these patients would not be offered CPAP, perhaps because they do not tolerate it.

Because none of the management options in this strategy involves examinations in the sleep laboratory, the corresponding time delays are assumed to be smaller (see next section on average time delays).

Figure 5 Layout of the distinct health states assumed by strategy 5 (home diagnosis with portable monitors and automatic titration of CPAP level at home)

CPAP: continuous positive airway pressure; repeat; repeating of a technically inadequate diagnostic PSG; test(+/−/tech inadeq): positive/negative/technically inadequate test result; titration (tech adeq/tech inadeq): technically adequate/inadequate CPAP level titration.

* In sensitivity analyses we assumed that this branch is not offered CPAP (see text).

We represent the model using a tree structure to enhance clarity. The actual Markov process is described in Appendix A.

Strategy 6 assumes management at home in at least two different nights. The first night is to set the diagnosis of OSAHS. The second night is to titrate the level of CPAP pressure for people who have a positive diagnosis.

Figure 5. Layout of the distinct health states assumed by strategy 5 (home diagnosis with portable monitors and automatic titration of CPAP level at home)

## Probabilities used in the simulations

Table 3 summarizes the probabilities (transition probabilities and other probabilities) used in the Markov processes. The following sections discuss in detail the choice of the probabilities, the range for the sensitivity analyses, and the rationale behind any assumptions. Explicit statements are made on the applicability of all probabilities to older adults (70 years old).

Table 3 Probabilities used in the Markov processes for a cohort of middle-aged people (50 years old)

Probability | Variable name | Baseline | Range | Rationale and comments
Prevalence of OSAHS among people with symptoms and signs (%) | prev | 54^*^ | 25, 75 | Summary prevalence from a synthesis of 30 prospective studies.35–61 The range is set to cover a wide span of plausible values (see text for details)
Diagnosis with facility-based PSG
Sensitivity (%) | S_PSG | 100 | 85, 100 | Assumption, given that the operating definition of OSAHS is an AHI of at least 15 events/hour with facility-based PSG; facility-based PSG is a reference strategy.
Specificity (%) | C_PSG | 100 | 85, 100 | Assumption, given that the operating definition of OSAHS is an AHI of at least 15 events/hour with facility-based PSG; facility-based PSG is a reference strategy.
Proportion of people who do not show up for the first scheduled full night PSG session | pNoShow_PSG | 0 | 0, 25 | Assumption; Range in sensitivity analyses varied to accommodate reasonably high “no show” values
Proportion of technically inadequate tests
• among those with OSAHS (%) | pFail_PSG1 | 4.6 | 2.7, 7.0 | Summary estimate and 95% CI from 19 studies reporting non-zero proportion of unsatisfactory examinations in facility-based PSG. 14,37,39,62–78 Assumption: probability of failure is independent of OSAHS status or AHI value
• among those without OSAHS (%) | pFail_PSG2 | 4.6 | 2.7, 7.0
Diagnosis with split-night PSG
Sensitivity (%) | S_SpNPSG | 89 | 76, 95 | Point estimate and 95% CI from a bivariate meta-analysis of 3 studies.79–81
Specificity (%) | C_SpNPSG | 94 | 52, 100 | Point estimate and 95% CI from a bivariate meta-analysis of 3 studies.79–81
Proportion of people who do not show up for the first scheduled split-night PSG session | pNoShow_SpNPSG | pNoShow_PSG | 0, 25 | Assumption; Range in sensitivity analyses varied to accommodate reasonably high “no show” values
Proportion of technically inadequate tests
• among those with OSAHS (%) | pFail_SpNPSG1 | 9.2 | 2.7, 14.0 | Assumption, two times higher than facility-based PSG (see text); the probability of failure is independent of OSAHS status or AHI value
• among those without OSAHS (%) | pFail_SpNPSG2 | 9.2 | 2.7, 14.0 | Assumption, two times higher than facility-based PSG (see text); the probability of failure is independent of OSAHS status or AHI value
Diagnosis with “prototype” home monitor
Sensitivity (%) | S_HomeDx | 90 | 83, 94 | Point estimate and 95% CI from a bivariate meta-analysis of 14 studies.39,41,50,55,58,59,63,64,82–86
Specificity (%) | C_HomeDx | 85^*^ | 67, 94 | Point estimate and 95% CI from a bivariate meta-analysis of 14 studies.39,41,50,55,58,59,63,64,82–86
Proportion of technically inadequate tests
• among those with OSAHS (%) | pFail_HomeDx1 | 8.9 | 6.6, 12.0 | Summary estimate and 95% CI from 23 studies reporting non-zero proportion of unsatisfactory examinations in the home setting, or clearly reporting no unsatisfactory examinations.37,39,47,48,50,52,55,60,62,65,66,69,73,78,87–94 Assumption: probability of failure is independent of OSAHS status or AHI value
• among those without OSAHS (%) | pFail_HomeDx2 | 8.9 | 6.6, 12.0
Technically adequate CPAP level titration study
Proportion with technically adequate manual (i.e., lab-based) CPAP titration study
• among those with OSAHS (%) | pTitr_manCPAP1 | 1-pFail_PSG1 | [depends on pFail_PSG1] | Assumed to be the same for split-night studies and whole night CPAP pressure titration studies
• among those without OSAHS (%) | pTitr_manCPAP2 | 1-pFail_PSG2 | [depends on pFail_PSG2] | Assumed to be the same for split-night studies and whole night CPAP pressure titration studies
Proportion with technically adequate automated (i.e., home-based) CPAP titration study
• among those with OSAHS (%) | pTitr_autoCPAP1 | 78 | 50, 100 | Based on a prospective cohort (Fletcher 2000^95^)
• among those without OSAHS (%) | pTitr_autoCPAP2 | 78 | 50, 100 | Based on a prospective cohort (Fletcher 2000^95^)
Average waiting time for a single study in the sleep labs for strategy 2 (weeks) | Dt_Lab | 13 | 4, 22 | Based on Flemons 2004^96^
Average waiting time for a single study in the sleep labs for strategies 3 and 4 (weeks) | [see text and Appendix B] | [see text and Appendix B] | [see text and Appendix B] | Based on the average waiting time in strategy 2 after accounting for the total number of studies in the sleep labs in strategies 3 and 4 [see Appendix B]
Average waiting time for a single study in the home setting (weeks) | Dt_Home | 2 | 0, 5 | Assumption; also assumed independent of the demand for sleep studies in the home setting

CI: confidence interval; CPAP: continuous positive airway pressure; OSAHS: Obstructive sleep apnea-hypopnea syndrome; PSG: polysomnography

* These two probabilities (prev, C_HomeDx) are assumed to be different among older adults (see text). All other probabilities were assumed tom be the same among younger people (~50 year olds) and older adults.

### Prevalence of OSAHS among people with suggestive symptoms (prev)

As discussed in the Terminology and Definitions section, OSAHS is operationally defined as AHI of at least 15 events/hour of sleep with a facility-based PSG study.

#### Estimates for middle-aged people (50 years old)

- Prev=54% in baseline analyses, ranging from 25% to 75% in sensitivity analyses (Table 3).

The prevalence of AHI suggestive of OSAHS among people who are referred to sleep laboratories for evaluation is higher compared to that in the general population, because referrals are based on suggestive symptoms and signs. We performed a meta-analysis to obtain the best estimate for the prevalence of OSAHS among middle-aged referrals. Eligible studies had a prospective or cross-sectional design and evaluated 11 or more adults; pertained to referrals by general practitioners, lung or other specialists for suspected OSAHS; did not screen participants with home monitoring devices or any form of sleep study to decide who will be assessed with facility-based PSG; and reported the proportion of people with AHI ≥15 events/hour of sleep. Only English-language studies were assessed, and no country restrictions were imposed.

Overall, 30 studies were eligible (Table 4).35–61 The median number of enrolled participants in the 30 studies was 67 (interquartile range: 45, 108), and in total, 2,901 people were evaluated. The majority of the participants were males (median percentage of males was 78%, interquartile range: 71, 83). The mean age of the participants was in the early fifties (median 50 years, interquartile range: 48, 52). Most participants were overweight or obese (the average BMI was on median 30.8 kg/m^2^, interquartile range: 29.6, 32.5).

The summary prevalence of AHI ≥15 events/hour of sleep was 54% (95% confidence interval: 48, 60%) in a random effects meta-analysis of the 30 studies. The summary estimate was very similar (56% [95% confidence interval: 48, 63%]) for the 27 studies that clearly described how apneas and hypopneas were defined in facility-based PSG. The boundaries of the 95% confidence interval defined the range of values in the sensitivity analyses.

Table 4 Prevalence of OSAHS (i.e., AHI≥15 events/hour of sleep with facility-based PSG) among people who were referred for sleep apnea evaluation

Author, Year Country | Participants | N | Mean age (y) | Mean AHI (Range) | AHI≥15 events/ h (%) | Male (%) | Mean BMI (kg/ m^2^) | Respiratory event definition for facility- based PSG
Clear definition of apneas and hypopneas
Levy, 1996 France | Referrals to sleep lab | 301 | 56 | 30 (ND) | 64 | ND | 32.0 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥50%
Chiner, 1999 Spain | Referrals to sleep center | 275 | 51 | 42 (15–101) | 79 | 89 | 30.0 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥50% or ↓effort (Th/AB) ≥50% or ↓airflow ≥50%; both with ↓SaO_2_ ≥4% or arousal
Alvarez, 2006 Spain | Referrals | 187 | 58 | 40 (ND) | 59 | 79 | 29.5 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) discernible with ↓SaO_2_ ≥4%
Issa, 1993 Canada | Referrals to sleep center | 129 | 48 | ND | 36 | 78 | 30.9 | Apnea: No airflow (therm) Hypopnea: ↓Effort (Th/AB) ≥50% with ↓SaO_2_ ≥3%
Rauscher, 1993 Austria | Referrals to sleep lab | 116 | ND | ND | 35 | 82 | ND | Apnea: No airflow (therm) Hypopnea: ↓Effort (Th/AB) ≥50% with ↓SaO_2_ ≥2% (if baseline absolute ≥94%) or ↓SaO_2_ ≥2% (if baseline absolute <94%)
Baltzan, 2000 Canada | Referrals to a sleep lab | 108 | 52 | 18 (ND) | 41 | 74 | 28.4 | Apnea: ↓Airflow (therm) >90% Hypopnea: ↓Airflow >50% with ↓ SaO_2_ ≥4%
Man, 1995 Canada | Referrals to sleep clinic | 104 | 47 | 17 (ND) | 27 | 78 | ND | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) >50%
Portier, 2000 France | Referrals to a pneumology clinic | 103 | 52 | 25.7 (ND) | 47 | 82 | 31.0 | Apnea: ↓airflow ≥75% Hypopnea: ↓Airflow ≥25% (& <75%)
Ryan, 1995 UK | Referrals to sleep clinic | 100 | 48 | ND | 46 | 83 | 29.6 | Apnea: No airflow (therm) with ↓SaO_2_ ≥4% in next 30s Hypopnea: ↓Airflow (therm) ≥25% with paradoxical movement, ↓effort (Th) ≥25%, and ↓airflow (AB) ≥15%
Mayer, 1998 France | Referrals to sleep lab | 95 | 53 | 43 (1, 147)^a^ | 75 | 83 | 30.7 | Hypopnea: ↓Airflow (therm) >50% with arousal or drop in SaO_2_ ≥4%
Parra, 1997 Spain | Referrals to pneumology clinic | 89 | 54 | 34 (ND) | 71 | 82 | 29.0 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) discernible with paradoxical motion (Th/AB) or cyclical dip in SaO_2_
White, 1995 USA | Referrals to sleep centers | 72 | 48 | 28 (0, 133)^a^ | 51 | 74 | 33.0 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥50% with ↓SaO_2_ ≥4% or EEG arousal
Gugger, 1997 Switzerland | Referrals | 67 | 51 | 26 (0, 96)^a^ | 58 | 87 | 31.0 | Apnea: ↓No airflow (therm) Hypopnea: ↓Airflow (therm) >50%
Ayappa, 2004 USA | Referrals to sleep center & healthy people | 66 | ND | 48 (4, 126) | 84 | 58 | 38.2 | Apnea: ↓Airflow (cannula, therm) ≥90% Hypopnea: ↓Airflow (Th/AB) ≥50% with ↓SaO_2_ ≥4% or arousal
Dingli, 2003 UK | Referrals to sleep center | 61 | 50 | 29 (ND) | 77 | 77 | 31.0 | Apnea: No airflow (cannula, therm) Hypopnea: ↓Effort (Th/AB) ≥50%
Su, 2004 USA | Referrals to sleep clinic | 60 | 45 | 27 (2, 122)^a^ | 55 | 42 | 35.6 | Apnea: No airflow (therm) with ↓Effort (Th/AB) ≥70% and ↓SaO_2_ ≥4% Hypopnea: No airflow (therm) with ↓Effort (Th/AB) ≥30% and ↓SaO_2_ ≥4%
Michaelson, 2006 USA | Referrals to sleep lab | 59 | 40 | 15 (1, 80)^a^ | 14 | 83 | 26.6 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥50% or ↓airflow <50% with ↓SaO_2_ ≥3% or arousal
Verse, 2000 Germany | Referrals to sleep clinic | 53 | 48 | 18 (0, 76) | 43 | 92 | 27.4 | Apnea: ↓Airflow (therm) >80% Hypopnea: ↓Airflow (therm) >50%
Reichert, 2003 Netherlands | Referrals to sleep center | 51 | 52 | 29 (0, 123)^a^ | 48 | 74 | 30.0 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥50% with ↓SaO_2_ ≥2%
van Surell, 1995 France | Referrals to sleep lab | 50 | 52 | 22 (0, 74)^a^ | 52 | 98 | 27.0 | Apnea: No airflow (therm) Hypopneas: ↓Airflow (therm) ≥50% with EEG arousal
Pang, 2006 USA | Referrals to a sleep lab | 39 | 52 | 32 (0, 111) | 69 | 44 | 35.7 | Apnea: No airflow (therm). Hypopnea: ↓Airflow (therm) discernible, with ↓Effort ≥30% and ↓SaO_2_ ≥4% or arousal
Pittman, 2004a USA | Referrals to sleep lab | 31 | 44 | ND | 71 | 70 | 33.7 | Apnea: No airflow (therm) Hypopnea: ↓airflow (therm) or ↓effort (Th/AB) ≥30%, with ↓SaO_2_ ≥4%
Pittman, 2004b USA | Referrals to a sleep lab | 30 | 43 | 32 (7, 82)^a^ | 76 | 72 | 33.9 | Apnea: No airflow (therm). Hypopnea: ↓Airflow (therm, Th/AB) ≥50% or “less reduction” with ↓SaO_2_ ≥3% or arousal
Zucconi, 1996 Italy | Referrals to sleep center | 30 | 53 | 32 (1, 86)^a^ | 65 | 68 | 30.7 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥40%
Penzel, 2004 Germany | Referrals to sleep lab | 21 | ND | 15 (0, 84)^a^ | 29 | ND | ND | Apnea: No airflow (therm) Hypopnea: ↓Effort (Th/AB) ≥50%
Mykytyn, 1999 Australia | Referrals to sleep lab | 20 | 50 | 25 (1, 79)^a^ | 35 | 100 | 30.6 | Apnea: no airflow (therm) Hypopnea: ↓effort (Th/AB) ≥50%
Rees, 1998 UK | Referrals to sleep lab | 20 | 48 | 39 (8–114) | 95 | 100 | 31.0 | Apnea: No airflow (therm) Hypopnea: ↓Effort (Th/AB) ≥50%
Unclear definition of apneas and hypopneas
Westbrook, 2005 USA | Referrals to sleep center | 299 | 48 | ND | 55 | 62 | ND | “Standard criteria”
Douglas, 1992 UK | Referrals to sleep lab | 220 | 50 | ND (0, 95)^a^ | 46 | 82 | ND | ND
Cooper, 1991 UK^m^ | Referrals to sleep center | 45 | ND | ND | 29 | 63 | ND | ND

Studies are ordered according to their definition of apneas and hypopneas and by decreasing total sample size. Note that the percentages are expressed with respect to the number of people that were analyzed with facility-based PSG, which may be smaller than the number of people who were enrolled in some studies.

AHI: Apnea-hypopnea index; BMI: body mass index; EEG: Electroencephalogram; h: hour (of sleep); N: number enrolled; ND: not described (not extractable); PSG: polysomnography; SaO_2_: Oxygen saturation (in arterial blood); Th/AB: thoracoabdominal bands; therm: thermistor; y: year(s).

a Data from digitized graph

#### Estimates for older adults (70 years old)

- prev=27% i.e., half of that assumed for younger adults.

None of the identified studies reported the prevalence of OSAHS (i.e., AHI ≥15 events/hour of sleep) among older adults who have been referred for OSAHS evaluation. Whenever individual patient data were reported in tables, the number of older adults was too small to allow for meaningful estimates: for example, two out of four people older than 60 years and one out of two people older than 70 years had AHI≥15 events/hour of sleep in Verse 2000.^59^

Here we are interested in the prevalence of OSAHS among older adults who are referred for sleep studies, not the prevalence among older adults in the general population. We estimated this number based on several considerations. The point estimate for our calculation was assumed to be 27 percent (i.e., half of what was set for middle-aged people). Briefly, the rationale is summarized as follows:

1. The prevalence of OSAHS among typical study enrollees, referred for sleep studies on the basis of suggestive symptoms and signs is 54 percent (see above).
2. If clinical signs and symptoms are equally strong predictors of OSAHS among elderly people as among younger people, the prevalence of OSAHS among the referred elderly would be again 54 percent. Note that the prevalence of OSAHS among elderly in the general population is a different quantity (see below, “Data on the prevalence of OSAHS among older adults in the general population”).
3. However, there are data to suggest that the association between symptoms and signs and OSAHS (AHI>15 events/hour) is not strong among older adults. This means that more older adults may have symptoms suggestive of OSAHS although they do not have OSAHS – equivalently, the prevalence of older adults who have OSAHS among older adults with suggestive symptoms and signs would be lower than that observed among typical study enrollees (~50 years old). (see below, “Data supporting that the association of symptoms and signs suggestive of OSAHS is not strong among older adults”)
4. Furthermore, among elderly people several non-OSAHS co-morbid conditions that may affect sleep indices are prevalent. This would change the prevalence values towards lower values.
  For example Cheyne-Stokes respiration is observed among people with heart failure, and may be misdiagnosed as obstructive sleep apnea by some portable monitors that collect a minimum set of physiologic signals.
5. Finally, if one makes testing for sleep conditions easier (perhaps allowing people with lower risk or even different indications to get tested – “indication creep”), the prevalence of OSAHS among people who are candidates to receive testing will be even lower.

##### Data on the prevalence of OSAHS among older adults in the general population

The prevalence of OSAHS among older adults often cited as higher than that of middle-aged people. Ancoli-Israel 1991 used a portable monitor (Respitrace, Medilog) to evaluate 427 people aged 65 years or older using random sampling from the general population.18 In ninety percent of the participants (385/427) RDI measurements were available. Forty four percent (170/385) were reported to have RDI≥20 events/hour. However, as the authors comment, the Respitrace portable monitor overestimated the number of hypopneas (data from their previous work). Moreover, the authors suggest that “most of the increase in apnea indices associated with aging occurs before age 65 is reached”.

In the population-based Sleep Heart Health Study the prevalence of AHI≥15 events/hour of sleep was 1.7-fold higher in people older than 60 years compared to people between 40 and 60 years of age.17 There was little increase in the prevalence of AHI≥15 events/hour of sleep in those older than 60 years old.17 The same leveling in the prevalence of the disease was found in population-based studies in Pennsylvania19 and Spain.20,21

##### Data supporting that the association of symptoms and signs suggestive of OSAHS is not strong among older adults

General practitioners and specialists refer people for OSAHS testing on the basis of suggestive symptoms or signs. It has been documented that among older adults these symptoms are less strongly associated with an AHI of at least 15 events/hour of sleep. In the Sleep Heart Health Study,17 the odds ratio for an AHI of at least 15 events/hour of sleep associated with 5.3 kg/m^2^ increase in BMI was 1.8 (95% confidence interval: 1.6, 2.0) for 50 year old people after age and race adjustments. The corresponding odds ratio for 70 year old people was 1.5 (95% confidence interval: 1.4, 1.7), yielding a relative adjusted odds ratio of 0.83 between these two age groups. Self-reported breathing pauses (sometimes and often versus never) are even less strongly associated with AHI ≥15 events/hour of sleep in older adults. Among 50 year olds the age and race adjusted odds ratio was 7.6 (95% confidence interval: 4.3, 13.5), whereas it was 2.7 (95% confidence interval: 1.7, 4.3) among 70 year old people. The adjusted relative odds ratio between the two age groups is 0.35.

### Sensitivity and specificity of facility-based PSG (S_PSG and C_PSG)

#### Estimates for middle-aged people (50 years old)

- S_PSG=100% and C_PSG=100% in baseline analyses, ranging from 85% to 100% in sensitivity analyses (Table 3).

The presence of OSAHS has been operationally identified with an AHI at least 15 events/hour of sleep (in the modeled population all people have suggestive symptoms and signs). Therefore, the baseline analysis assigns to facility-based PSG perfect diagnostic sensitivity and specificity for the identification of AHI≥15 events/hour (both were set to 100% for the main analyses).

We did not find values for the sensitivity and specificity of facility-based PSG in the published literature. Studies describing the night-to-night variability of facility-based PSG suggest that variability is present, but a single facility-based PSG may be sufficient.97 A study assessing the night-to-night variability of facility-based PSG in children suggested that 85% of children would be accurately classified by the first facility-based PSG.98

We ranged these values in sensitivity analyses between 85% and 100%, an arbitrarily chosen wide range guided by the aforementioned caveats.

#### Estimates for older adults (70 years old)

We used the same probabilities as in the baseline analyses. The implicit assumption here is that the sleep physician in the sleep lab would be able to distinguish OSAHS from other conditions that may affect sleep without being OSAHS (e.g., Cheyne-Stokes respiration), as discussed previously under the “Prevalence (prev)” section.

### Sensitivity and specificity of split-night studies (S_SpNPSG and C_SpNPSG)

#### Estimates for middle-aged people (50 years old)

- S_SpNPSG=89% in baseline analyses, ranging from 76% to 95% in sensitivity analyses (Table 3).
- C_SpNPSG=94% in baseline analyses, ranging from 52% to 100% in sensitivity analyses (Table 3).

We did not find extensive data on the sensitivity and specificity of split-nigh studies compared to full night PSG. We identified three English language studies that allowed us to calculate the sensitivity and specificity of split-night PSG to predict AHI≥15 events/hour of sleep with full night facility-based PSG.79–81 In all three studies we extracted the needed information after digitizing Bland-Altman plots79 or scatter plots80,81 from the original paper. Table 5 summarizes these studies.

Sanders 1991^81^ assessed people who were referred only on the basis of history or symptoms. In the other two studies, patients were screened with overnight oximetry or were known to have AHI≥10 events/hour of sleep (Table 5). Overall, the three studies assessed predominantly male and obese people, with baseline AHI values that were on average as high as 40–44 events/hour of sleep with full night PSG.

We performed a bivariate meta-analysis using a generalized linear mixed model to estimate the average sensitivity and specificity of split-night studies to predict AHI≥15 events/hour of sleep in facility-based PSG.99–101 The values obtained from the bivariate meta-analysis are similar to the values obtained from separate meta-analyses.

#### Estimates for older adults (70 years old)

We used the same probabilities as in the baseline analyses. The implicit assumption here is that the sleep physician in the sleep lab would be able to distinguish OSAHS from other conditions that may affect sleep without being OSAHS (e.g., Cheyne-Stokes respiration), as discussed previously under the “Prevalence (prev)” section.

Table 5 Sensitivity and specificity of split-night studies to predict OSAHS (i.e., AHI≥15 events/hour of sleep with full night facility-based PSG)

Author, Year Country | Participants | N | Mean age (y) | Mean AHI (Range) | AHI≥15 events/h (%) | Male (%) | Mean BMI (kg/m^2^) | Respiratory event definition for facility- based PSG | Sensitivity (95% CI) [%] | Specificity (95% CI) [%]
Sanders, 1991 USA | Consecutive referrals for symptoms | 50 | 50 | 44 (0, 114)^a^ | 65^a^ | ND | ND | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥30% without reduction in effort | 97 (83, 100)^a^ | 82 (57, 96)^a^
Chung, 1998 Hong Kong | Consecutive patients with AHI>10 events/h | 37 | 42 | 44 (11, 113)^a^ | 89^a^ | 95 | 28.8 | ND | 82 (65, 93)^a^ | 100 (40, 100)^a^
Fanfulla, 1997 Italy | Referrals on the basis of symptoms and overnight oximetry | 29 | 54 | 40 (9, 95)^a^ | 72^a^ | 93 | 40.0 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥50% | 86 (64, 97)^a^ | 100 (63, 100)^a^
| | | | | | | | Bivariate meta-analysis | 89 (76, 95) | 94 (52, 100)
| | | | | | | | Separate meta-analyses | 86 (76, 92) | 86 (66, 95)

AHI: Apnea-hypopnea index; BMI: body mass index; CI: confidence interval; h: hours of sleep; N: number enrolled; therm: thermistor; PSG: polysomnography; y: year(s).

All available English language studies that reported or allowed the calculation of sensitivities and specificities of split-night PSG were included. See text for discussion.

a Data extracted from digitized graphs

### Sensitivity and specificity of home monitoring (S_HomeDx and C_HomeDx)

#### Estimates for middle-aged people (50 years old)

- S_HomeDx=90% in baseline analyses, ranging from 83% to 94% in sensitivity analyses (Table 3).
- C_HomeDx=85% in baseline analyses, ranging from 67% to 94% in sensitivity analyses (Table 3).

Eligible studies assessed the ability of type III and type IV_3+_ (type IV monitors recording at least 3 bioparameters) to predict AHI≥15 events/hour of sleep in facility-based PSG among 11 or more adults. Studies of portable monitors in the home setting were included irrespective of whether manual or automated scoring was used. Of studies performed in the lab setting, only those that provided results with automated scoring were used.

Fourteen studies described in 13 publications39,41,50,55,58,59,63,64,82–86 fulfilled these criteria; six pertained to type III monitors39,55,59,82–84 and eight to type IV_3+_ monitors.41,50,58,63,64,85,86 Six studies received grade “A”39 or “B”41,50,51,55,58,59,64,85,86 for their methodological quality, and the remaining received grade “C”. The 14 studies are described in Table 6. Overall, the majority of the participants were male. In all studies the average BMI was above 27 kg/m^2^ and in 10 it was more than 30 kg/m^2^. The mean age of the participants across the 10 studies ranged between 43 and 57 years. Nine different portable monitor types were used. We emphasize that the studies in Table 6 are heterogeneous with respect to the type of monitor, the channels recorded by these monitors and the definition of the respiratory events in the index and reference tests.

We were able to extract the counts for the 2 by 2 tables in nine out of fourteen studies (the ones in Table 6 for which confidence intervals for sensitivity and specificity are shown). We estimated the counts in the 2 by 2 tables in the remaining studies from the reported sensitivities and specificities, assuming that the prevalence of AHI≥15 events/hour was 54% (equal to the summary prevalence estimate that was calculated in a previous section).

Table 6 Sensitivity and specificity of type III monitors (automated scoring) to predict OSAHS (i.e., AHI≥15 events/hour of sleep in facility-based PSG)

Author, Year Country | Partici- pants | N | Mean age (y) | Mean AHI (Range) | Male (%) | Mean BMI (kg/ m^2^) | Respiratory event definition for facility- based PSG | Type III monitor (automated scoring except for Dingli 2003)
Author, Year Country | Partici- pants | N | Mean age (y) | Mean AHI (Range) | Male (%) | Mean BMI (kg/ m^2^) | Respiratory event definition for facility- based PSG | Name | Respiratory event definition | Att /hook- up | Sensitivity (95% CI) [%] | Specificity (95% CI) [%]
Home setting - type III monitors
Dingli, 2003 UK | Referrals to sleep center | 61 | 50 | 29 (ND) | 77 | 31.0 | Apnea: No airflow (cannula, therm) Hypopnea: ↓Effort (Th/AB) ≥ 50% | Embletta | Default settings | No/Tech | 95 (77, 100) | 82 (57, 96)
Home Setting – type IV3+ monitors
Schafer, 1997 Germany | Referrals | 114 | 56 | 29 (ND) | 88 | 30.8 | Apnea: No airflow (therm). Hypopnea: ↓Airflow (therm) ≥ 50% ↓SaO_2_≥ 4% or arousal | Mesam IV | ↓SaO_2_≥ 4%, or ↓SaO_2_≥ 2% with visible change in HR | ND/Tech | 83 (NE) | 62 (NE)
Bar, 2003 Israel | Referrals to sleep center | 14 | ND | 31 (4, 78) | ND | ND | Apnea/Hypopnea: ↓Airflow (therm, Th/AB) ≥ 50% or “less reduction” with ↓SaO_2_≥ 3% or arousal | Watch Pat 100 | ND | No/P | 80 (46, 95) | 50 (12, 88)
Pittman, 2004 USA | Referrals to sleep lab | 30 | 43 | 32 (7, 82) | 72 | 33.9 | Apnea: No airflow (therm). Hypopnea: ↓Airflow (therm, Th/AB) ≥ 50% or “less reduction” with ↓SaO_2_≥ 3% or arousal | Watch Pat 100 | One of three:; 1. ↓PAT amplitude with acceleration in pulse rate or ↑ wrist activity; 2. ↓PAT amplitude with ↓SaO_2_ ≥3% (<4%); 3. ↓SaO_2_ ≥4% | ND | 95 (74, 99) | 100 (59, 100)
Specialized sleep unit – type III monitors
Verse, 2000 Germany | Referrals to sleep clinic | 53 | 48 | 18 (0, 76) | 92 | 27.4 | Apnea: ↓Airflow (therm) >80% Hypopnea: ↓Airflow (therm) >50% | Poly-Mesam | Apnea: ↓Airflow (therm) >80% Hypopnea: ↓Airflow (therm) >50% | ND/Tech | 91 (72, 99) | 97 (83, 100)
Reichert 2003, Netherlands | Referrals to sleep center | 51 | 52 | 29 (0, 123) | 74 | 30.0 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥50% with ↓SaO_2_≥2% | Nova-Som QSG | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥50% with drop in SaO_2_≥2% | Yes/ND | 95 (77, 100) | 64 (45, 80)
Calleja, 2002 Spain | Referrals to sleep lab | 86 | 52 | 34 (ND) | 89 | 30.1 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) discernible with arousal or ↓SaO_2_ ≥3% | Merlin | ND | No/Tech | 64 (NE) | 73 (NE)
Fietze, 2002 Germany | Referrals | 66 | 51 | 24 (ND) | 98 | 32.9 | Apnea: ↓Airflow (therm) >85% Hypopnea: ↓Airflow (therm) >50% with ↓SaO_2_ ≥3% | Merlin | Apnea/Hypopnea: ↓SaO_2_≥3% | ND | 91 (NE) | 100 (NE)
Claman, 2001 USA | Referrals to sleep center | 42 | 54 | 26 (0, 90) | 74 | 30.6 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥50% with ↓SaO_2_ ≥4% | Bedbugg | ND | ND | 86 (64, 95) | 95 (73, 99)
Specialized sleep unit – type IV_3+_ monitors
Ayas, 2003 US | Suspected OSAHS | 30 | 47 | 23 (1-94) | 63 | 31.0 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥50% or ≥airflow <50% with ↓SaO_2_ ≥3% or arousal | Watch Pat 100 | One of three:; 1. ↓PAT amplitude with acceleration in HR or ↑ wrist activity; 2. ↓PAT amplitude with ↓SaO2 ≥3% (<4%); 3. ↓SaO2 ≥4% | ND | 93 (NE) | 73 (NE)
Pittman, 2004 USA | Referrals to sleep lab | 30 | 43 | 32 (7, 82)^b^ | 72 | 30.9 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) ≥50% or ↓airflow <50% with ↓SaO_2_ ≥3% or arousal | Watch Pat 100 | One of three:; 1. ↓PAT amplitude with acceleration in HR or ↑ wrist activity; 2. ↓PAT amplitude with ↓SaO2 ≥3% (<4%); 3. ↓SaO2 ≥4% | ND | 91 (70, 98) | 86 (42, 98)
Esnaola, 1996 Spain | Referrals to sleep center | 152 (150) | 57 | 27 (ND) | 89 | 29.8 | Apnea: No airflow (therm) Hypopnea: ↓Airflow (therm) discernible with ↓SaO_2_ ≥4% or arousal | Mesam IV | ND | ND | 97 (NE) | 36 (NE)
Issa, 1993 Canada | Referrals to sleep center | 129 | 48 | ND | 78 | 30.9 | Apnea: No airflow (therm) Hypopnea: ↓Effort (Th/AB)≥50% with ↓SaO_2_≥3% | SnoreSat | ↓SaO_2_>3% and amplitude of snoring | ND/Tech | 87 (74, 94) | 96 (89, 99)
van Surell, 1995 France | Referrals to sleep lab | 50 | 52 | 22 (0, 74) | 98 | 27.0 | Apnea: No airflow (therm) Hypopneas: ↓Airflow (therm) ≥50% with EEG arousal | CID 102 | Apnea: tracheal silence Hypopneas: short tracheal silence (for ≥7s & <10s) with cyclic ↓SaO_2_≥4% and ↑SaO_2_ within 50s | ND/Tech | 73 (53, 87) | 63 (42, 79)

Whenever NE (not estimable) is listed instead of a confidence interval for sensitivity and specificity, we could not extract the counts in the 2by2 tables, with a single exception (specificity, Rees 1998).

Att: attended; AHI: apnea-hypopnea index in events/hour of sleep; EEG: electroencephalogram; N: Number enrolled; ND: not described; NE: not estimable; PSG: polysomnography; Tech: technologist; Th/AB belts: thoracoabdominal belts; therm: Thermistors used in airflow estimation; y: year(s).

Respiratory events across all studies were of at least 10 seconds duration unless otherwise noted. Studies ordered by setting, monitor type, quality and size after grouping per monitor make.

We performed bivariate meta-analyses to estimate the summary sensitivity and specificity99–101 of a prototype portable monitor. This hypothetical monitor is has sensitivity and specificity similar to that of type III and type IV_3+_ monitors, as discussed earlier. The results of the bivariate meta-analyses were corroborated with independent, separate meta-analyses of sensitivity and specificity across the synthesized studies.

We emphasize once more that the studies in Table 6 are heterogeneous with respect to the type of monitor, the channels recorded by these monitors and the definition of the respiratory events in the index and reference tests. However, we preferred to use all studies in the main analyses all studies, because estimates for subgroups were generally consistent (Table 7). The summary sensitivity was 90% (95% confidence interval: 83, 94%), and the summary specificity was 85% (95% confidence interval: 67, 94%) in bivariate meta-analyses. As shown in Table 7, the estimates were similar when we excluded studies for which we imputed the 2 by 2 table counts; when we excluded studies that received grade “C” for their methodological quality; and among studies in the home and the laboratory settings. Independent, separate meta-analyses tended to underestimate the corresponding results from bivariate meta-analyses.

Table 7 Meta-analysis of the ability of type III monitors (home setting or automated scoring) to predict OSAHS (i.e., AHI≥15 events/hour in facility-based PSG)

(Subgroup) summary | N (subjects) | Sensitivity (95% CI) [%] | Specificity (95% CI) [%]
Bivariate meta-analysis
All studies^a^ | 14 (879) | 90 (83, 94) | 85 (67, 94)
Studies with 2by2 table counts available | 9 (440) | 89 (83, 94) | 89 (72, 96)
A and B quality studies^b^ | 10 (678) | 92 (86, 96) | 82 (62, 93)
Studies in the home setting | 4 (207) | 92 (75, 98) | 58 (46, 69)
Studies in the lab setting | 10 (672) | 89 (81, 94) | 89 (73, 96)
Separate meta-analyses
All studies^a^ | 14 (879) | 75 (70, 79) | 63 (56, 68)
Studies with 2by2 table counts available | 9 (440) | 70 (63, 76) | 75 (66, 83)
A and B quality studies^b^ | 10 (678) | 75 (69, 80) | 60 (53, 66)
Studies in the home setting | 4 (207) | 84 (75, 90) | 56 (45, 67)
Studies in the lab setting | 10 (672) | 72 (66, 77) | 66 (58, 72)

CI: confidence interval

a In five studies the counts in the 2by2 table were not reported, and they were calculated from the reported sensitivities and specificities, assuming a prevalence of 54% for AHI≥15 events/hour of sleep

b In three studies the counts in the 2by2 table were not reported, and they were calculated from the reported sensitivities and specificities, assuming a prevalence of 54% for AHI≥15 events/hour of sleep

#### Estimates for older adults (70 years old)

- S_HomeDx=90% same as in younger adults.
- C_HomeDx=70% (vs 85% among 50 year olds).

We did not identify data on the sensitivity and specificity of portable monitors for the diagnosis of OSAHS (as operationally defined here) among older adults. Therefore, the corresponding estimates among older adults are based on assumptions.

As mentioned in the section on prevalence, the association of symptoms and signs suggestive of OSAHS is not strong among older adults. Moreover, conditions other than obstructive that may affect sleep quality are prevalent among older adults.

It is assumed that a detailed and comprehensive sleep study that evaluates neurophysiological and respiratory signals in the sleep laboratory can correctly identify OSAHS in elderly people.

A portable monitor records respiratory information and may result in false positive diagnoses among older adults, because it does not record neurophysiologic information needed to distinguish OSAHS from other conditions that affect sleep. For this reason we reduced the specificity of portable monitors to 70 percent for older adults. This is equivalent to assuming 15 percent additional false positives for portable monitors among older adults. The assumption is reasonable especially in the presence of “indication creep”, i.e. when a wider base of patients is being referred for sleep studies, rather than the typical enrollees in the published studies. However, there is no obvious reason that justifies a similar change in the sensitivity of portable monitors.

### Proportion of technically inadequate tests for facility-based PSG (pFail_PSG1 and pFail_PSG2)

#### Estimates for middle-aged adults (50 years old)

- pFail_PSG1 and pFail_PSG2=4.6% in baseline analyses, ranging from 2.7% to 7.0% in sensitivity analyses (Table 3).

Our main estimates were derived from 19 studies that reported non-zero proportion of unsatisfactory (technically inadequate) examinations in facility-based PSG14,37,39,62–78 (Table 3; 4.6% [95% confidence interval: 2.7, 7.0%]). When we included 9 studies that reported 0 unsatisfactory tests,46,50,51,60,77,88,102–104 the corresponding estimate became 2.7% (95% confidence interval: 1.2, 4.8%; n=28 studies). However, studies that reported zero unsatisfactory examinations may have excluded any unsatisfactory examinations or repeated them without mentioning it in the text.

We assumed that the probability of technically inadequate testing is independent of OSAHS status, and that such failures are conditionally independent (i.e., a person who had a technically inadequate test the first time has the same probability for a technically inadequate test the second time he or she is tested).

It may be argued that the corresponding probability would be different (e.g., smaller) the second time an exam is repeated (because more emphasis would be given to avoid e.g., an error). However, because only a minority of patients ever undergo repeat sleep studies, assuming a different probability for technically inadequate repeat studies does not have a major effect in the assessed outcomes.

We should emphasize that this probability implicitly models the “first night” effect. The existence of a “first night effect” has been hypothesized because of the lack of familiarity with the sleep study procedures.105,106 It is postulated that sleep quality will improve once people become familiar with the sleep-study procedures. However, a first night effect was not documented in repeated home-based measurements in the Sleep Heart Health Study.107

#### Estimates for older adults (70 years old)

We used the same probability as for middle-aged people. There are no indications that the rate of technically inadequate studies or data loss would be different for older people. For home monitoring this is supported from data from the Sleep Heart Health Study.69 We assumed that the same would be true for facility-based PSG.

### Proportion of technically inadequate split-night studies (pFail_SpNPSG1 and pFail_SpNPSG2)

#### Estimates for middle-aged adults (50 years old)

- pFail_SpNPSG1 and pFail_SpNPSG2=9.2% in baseline analyses, ranging from 2.7% to 14.0% in sensitivity analyses (Table 3).

A split-night study may be technically inadequate because the first half (diagnostic part) or the second half (CPAP level titration) is technically inadequate. In the absence of relevant data we assumed that each part of the split-night study has the same probability to be technically inadequate as a diagnostic facility-based PSG study. Therefore, this probability was set to be double of the probability for technically inadequate facility-based PSG studies. The range for the sensitivity analyses was accordingly augmented (from 2.7 percent to 14 percent).

It may be argued that the corresponding probability would be different (e.g., smaller) the second time an exam is repeated (because more emphasis would be given to avoid e.g., an error). However, because only a minority of patients ever undergo repeat sleep studies, assuming a different probability for technically inadequate repeat studies does not have a major effect in the assessed outcomes.

As commented in the previous section on the corresponding probability in facility-based PSG, this probability implicitly models the “first night” effect.

We assumed that this probability is independent of OSAHS status and to remain the same for people who have already had a technically inadequate study in the past (conditional independence).

#### Estimates for older adults (70 years old)

We used the same probability as for middle-aged people. There are no indications that the rate of technically inadequate studies would be different for older people. For home monitoring this is supported from data from the Sleep Heart Health Study.69 We assumed that this would be true for split-night studies as well.

### Proportion of technically inadequate tests for portable monitors in the home setting (pFail_HomeDx1 and pFail_HomeDx2)

#### Estimates for middle-aged adults (50 years old)

- pFail_HomeDx1 and pFail_HomeDx2=8.9% in baseline analyses, ranging from 6.6% to 12.0% in sensitivity analyses (Table 3).

There were 23 studies that reported non-zero proportion of unsatisfactory tests or clearly stated zero unsatisfactory tests for portable monitors in the home setting.37,39,47,48,50,52,55,60,62,65,66,69,73,78,87–94 8.9% (95% confidence interval: 6.6, 12.0%). The largest study is a report from the Sleep Heart Health Study. Kapur 2000^69^ examined factors associated with sensor loss using unattended home sleep monitoring with a type II device (Compumedics PS-2). Approximately 9 percent of 6802 people did not have a successful first sleep examination. Of these, approximately 4 percent (279/6802) had more than one attempt until a successful sleep study, and 5 percent (362/6802) had all attempts (in the majority the single attempt) unsuccessful.

Some portable home monitors have the ability to alert the evaluated person if a probe is not correctly or does not give a valid signal (e.g., Novasom QSG, as described in Reichert 2003^55^). In the Reichert 2003 study 6 percent (3/51) of home recordings were lost secondary to chip malfunction. An additional 3 people (6 percent) did not use the machine at al. Therefore, our estimate is not incompatible with the rate of inconclusive examinations in the Reichert study.

It may be argued that the corresponding probability would be different (e.g., smaller) the second time an exam is repeated (because more emphasis would be given to avoid e.g., an error). However, because only a minority of patients ever undergo repeat sleep studies, assuming a different probability for technically inadequate repeat studies does not have a major effect in the assessed outcomes.

We assumed that this probability is independent of OSAHS status and to remain the same for people who have already had a technically inadequate study in the past (conditional independence).

#### Estimates for older adults (70 years old)

There are no indications that the rate of inconclusive studies or data loss would be different for older people, as found in a report of the Sleep Heart Health Study.69 Therefore, the same probability was used for older adults (Medicare beneficiaries).

### Probability of technically adequate CPAP titration study in facility-based PSG (pTitr_manCPAP1 and pTitr_manCPAP2)

#### Estimates for middle-aged adults (50 years old)

- pTitr_manCPAP1 and pTitr_manCPAP2=95.4% in baseline analyses, ranging from 93.0% to 97.3% in sensitivity analyses (Table 3).

The rate of technically inadequate CPAP titration studies in facility-based PSG was assumed to be equal to the rate of technically inadequate diagnostic PSG. The probability to have a technically adequate CPAP titration study (in full night therapeutic PSG) is 100% minus the probability of failure, or 95.4%.

The corresponding number was assumed to be independent of OSAHS status and to remain the same for people who have already had a technically inadequate study in the past (conditional independence).

#### Estimates for older adults (70 years old)

We used the same probabilities as in the baseline analyses.

### Probability of technically adequate CPAP titration study in the home setting (pTitr_autoCPAP1 and pTitr_autoCPAP2)

#### Estimates for middle-aged adults (50 years old)

- pTitr_autoCPAP1 and pTitr_autoCPAP2=78% in baseline analyses, ranging from 50% to 100% in sensitivity analyses (Table 3).

Fletcher 2000^95^ describes a prospective cohort of 63 people who were managed for suspected OSAHS without facility-based polysomnography. The cohort was offered home monitoring and auto-titration of CPAP at home. Of the 45 people who were diagnosed with OSAHS (using a cutoff of RDI=10 events/hour in bed) 35 (78%) had completed their automated CPAP titration studies. This value was selected in the baseline analyses, but was subjected to wide sensitivity analyses (from 50% to 100%).

We assumed that this probability is independent of OSAHS status and to remain the same for people who have already had a technically inadequate study in the past (conditional independence).

#### Estimates for older adults (70 years old)

We used the same probabilities as in the baseline analyses.

### Average waiting time for a sleep study in the lab setting

This is a very central quantity, in the modeling. Unfortunately, there are no detailed data on the average waiting time per sleep study in the lab setting. Furthermore, regional differences in average waiting times within the US are may also be large. Therefore, we provide results across a range of possible values.

The architecture of the modeling is such that the relative change in the average waiting time in the sleep labs across strategies is the constant (see below and Appendix B). The average waiting time for a sleep study in the lab in each strategy depends on the total number of facility-based sleep studies that expected to be performed in the strategy: it will be longer for the strategy with the most sleep studies in the lab setting.

As discussed below, we found data on the average waiting time for strategy 2. Appendix B shows how one can adjust the corresponding average waiting time for strategies 3, 4 and 5. Briefly, one takes into account the expected workload of the sleep labs in strategies 3, 4 and 5 relatively to strategy 2, and adjusts the corresponding average waiting times.

#### Estimates of average waiting time in strategy 2 for middle-aged adults (50 years old)

The time delay from referral to a diagnostic facility-based PSG may be highly variable and may depend on each country’s the health system, the relative workload of the sleep laboratories, the reimbursement policies, and the exact diagnosis.96 In 2002 the population of the US was 280 million, the total number of sleep labs was 1,292, and the estimated annual rate of sleep tests performed was 1.17 million for the whole country (or 427 per 100,000 people per year).96

Flemons 2004 reports that, on average, the waiting time from referral to CPAP initiation ranges widely from 2 to 10 months in the USA.96 The authors comment that there is great variability across states and across urban or rural centers, and centers affiliated with universities versus centers that are not. Similarly long delays are described in Canada (and were the impetus for a recent RCT comparing home-based management with facility-based PSG108).

Shariq 2004 on the other hand reports (in a letter109) that the average waiting time across approximately 350 out of 2,515 accredited and non-accredited sleep labs was “between 2 and 3” weeks.109 It is unclear whether the average waiting times are similar across the more than 2,000 remaining sleep labs, or whether this estimate is robust to the many systematic errors that a survey study may have. Contrary to the Flemons 2004 paper, Shariq 2004 does not give important methodological details on sampling, survey questions and other important aspects, and does not discuss potential systematic errors and their impact. Therefore, the main analyses used estimates from the Flemons 2004 paper.

For the main analyses we used the following rationale to obtain the average waiting time for a single sleep study:

1. The average time from referral to CPAP initiation is 26 weeks (half a year, i.e., the midpoint between 2 and 10 months).
2. In the Flemons 2004 paper, most participating US centers used facility-based PSG to diagnose OSAHS and a second session to titrate CPAP level. Assuming equally long average delay to diagnose OSAHS and to titrate CPAP level for those with positive diagnoses, the mean delay for each session in the sleep lab would be 13 weeks.
3. Because average time delay for a sleep study varies in different settings, we present estimates across a wide range, from 4 weeks to 26 weeks for a single sleep study (corresponding to the range of the average delays from referral to CPAP initiation reported in the Flemons 2004 article96).

The corresponding estimates for strategies 3, 4 and 5 are derived based on the strategy 2 estimates as described in Appendix B.

#### Estimates for older adults (70 years old)

We used the same probabilities as in the baseline analyses, following the adjustments described in Appendix B.

### Average waiting time for a sleep study in the home setting

Contrary to the average waiting time in the sleep lab setting, we assumed that the average waiting time for a sleep study in the home setting is independent of the total volume of sleep studies in the home setting.

#### Estimates for middle-aged adults (50 years old)

In the absence of relevant data, we assumed that the time delay for a home-based study (either diagnosis or CPAP titration) would be only 2 weeks. This is reasonable for a health system that has purchased enough sleep monitors to cover its needs (i.e., a health system that has reached a “steady-state” in terms of acquiring necessary equipment), and factors in the time needed to read the exams and delays secondary to bureaucratic processes.

We varied the corresponding average delay from 0 to 5 weeks (i.e., longer than the shortest mean delay for sleep studies in the lab).

#### Estimates for older adults (70 years old)

We used the same probabilities as in the baseline analyses.

### Proportion of people who do not show up for the first scheduled full night or split-night PSG session

The main analyses assume that all people will show up for a sleep study in the lab setting (i.e., for a full night or a split-night PSG study). However, secondary to reviewer comments, we performed sensitivity analyses assuming that up to 25% of people scheduled for their first sleep lab session will not appear. We assumed that these patients will not go on to the downstream health states of the pertinent health strategy.

This applies to strategy 2 (all diagnoses are performed with facility based PSG), strategy 3 (all diagnoses are performed with split-night PSG) and strategy 5 (where people with negative home monitoring diagnoses are invited for split night PSG studies). We did not perform these sensitivity analyses for strategy 4 (people with positive home diagnoses are further verified with split-night studies). This is because people with a positive diagnosis in the home setting have an extra motive to verify their condition and start treatment if needed. Furthermore this sensitivity analysis is not applicable to strategy 1 (none is ever diagnosed or treated), strategy 6 (management outside the sleep lab) and strategy 7 (all on CPAP).

As per reviewers’ suggestions we did not perform the corresponding sensitivity analyses for a “no show” for portable monitor studies.

## Outcomes

The following outcomes were considered:

1. Proportion of people who are offered CPAP (i.e., essentially those with positive diagnoses)
  a. Among all participants in the whole cohort
  b. Among people with OSAHS (see “Terminology and Definitions” on the definition of OSAHS and related discussion)
  c. Among people without OSAHS
2. Mean time until diagnosis.
  a. Among all participants in the whole cohort
  b. Among people with OSAHS
  c. Among people without OSAHS
  This outcome is meaningful only among strategies 2 to 5, where tests to diagnose OSAHS are used.
3. Mean time until successful CPAP titration among people with a true positive diagnosis of OSAHS (in their last sleep study)

Time to successful CPAP titration is not a meaningful outcome to evaluate in strategy 1 (none is ever tested or offered a CPAP titration study) and strategy 6 (all are offered a CPAP titration study).

Moreover, it is not meaningful to evaluate among people who received a negative diagnosis for OSAHS in their (last) diagnostic study, as they would never be offered a CPAP titration study in the modeled strategies.

Finally, people who have received a false positive diagnosis of OSAHS the corresponding time would be the average time to a (final) technically adequate CPAP titration study. This would have exactly the same length as the average time to successful CPAP titration among people with a true positive diagnosis of OSAHS.

### Calculation of time to diagnosis and time to technically adequate CPAP titration study

To calculate the outcomes of time to diagnosis and time to CPAP titration we counted the total number of expected sleep studies in each strategy and multiplied with the (strategy-specific) average time-delay for a sleep study (in the lab or at home – see previous section for estimates).

## Sensitivity analyses

Main analyses use the baseline values of the transition probabilities. The robustness of the baseline results was assessed with univariate sensitivity analyses. In these explorations, the value of each transition probability is changed to cover the whole range of probable values that are prespecified in Table 3, while keeping all other variables at baseline.

We performed one-way sensitivity analyses for the scenario that focused on middle-aged adults. The range of values used in the sensitivity analyses adequately covers plausible values for the alternative scenario that focuses on older people.

Sensitivity analyses were run for all outcomes. However, for parsimony, we present in detail only the most influential variables for outcome 1a, outcome 2a and outcome 3, which are the clinically more relevant outcomes.

During sensitivity analyses, the ranking of the different strategies with respect to the aforementioned outcomes may change. Typically, the threshold where such changes occur is described. However, in this case we are not evaluating utilities and costs, but several quite distinct outcomes. Therefore the interpretation of the thresholds at which the ranking of the various strategies changes is not straightforward. For this reason we decided not to report exact thresholds, but to describe them qualitatively.

We also performed two-way sensitivity analyses, by simultaneously varying pairs of variables over the whole range of prespecified probable values, while keeping all other probabilities at baseline. This was done for pairs of variables that had the most influence in one-way sensitivity analyses. Because their results do not add substantially to the interpretation of the simulations, they are not reported in detail.