# Introduction

## Obstructive Sleep Apneas-Hypopnea Syndrome (OSAHS)

Sleep Apnea is a relatively common disorder that can affect all ages. The condition is characterized by periods of disturbed airflow patterns during sleep time, namely reduced airflow (hypopnea) or airflow cessation (apnea). It is postulated that both types of airflow disturbance have similar pathophysiology and bear the same clinical significance.1 Obstructive sleep apnea-hypopnea syndrome (OSAHS) is the most common type of the condition (apneas and hypopneas of central and mixed central and obstructive etiology comprise the other forms).1 OSAHS has been associated with a variety of adverse clinical outcomes such as mortality secondary to stroke and cardiovascular events,2–4 decreased quality of life,5 cardiovascular disease and stroke,2,6 hypertension,7–9 diabetes and other metabolic abnormalities,10,11 as well as increased likelihood for driving12,13 and other types of accidents.

## Assessing the presence and quantifying the severity of OSAHS

The severity of OSAHS is typically quantified by the number of apneas and hypopneas per hour of sleep, a quantity that has been termed Apnea-Hypopnea Index (AHI). Specific cutoffs are typically used to establish the diagnosis of OSAHS.1,14 For example, as of this writing, the Medicare criteria for reimbursement of continuous positive airway pressure (CPAP) therapy are AHI ≥15 events/hour, or AHI ≥5 events/hour associated with symptoms (e.g., daytime somnolence and fatigue). However, a variety of AHI thresholds ranging between 5 and 40 have been used as suggestive of OSAHS in different studies.

We emphasize that AHI alone is not sufficient to classify people into those with and without OSAHS. This is because AHI does not correlate well with the intensity of symptoms and signs (e.g., day somnolence, fatigability),14 or with daytime measures of quality of life, well-being, and cognitive performance.15 There are probably no clinical or statistical differences between patients who differ only by a few points in the AHI.

Approximately two to four percent of middle-aged women and men, respectively, have been estimated to have an AHI≥5 events/hour and excessive daytime somnolence in the population-based Wisconsin Sleep Cohort Study.5 Using an AHI cutoff of ≥5 events/hour without the symptoms of excessive daytime sleepiness puts the prevalence at 9% for women and 24% for men. The symptom of excessive daytime sleepiness is quite variable and not always present in patients with OSAHS. Most people suffering from OSAHS remain undiagnosed and untreated.5 More recent studies also suggest a high prevalence (i.e., prevalence of AHI ≥ 5 in adults age 30–69 of 17%), perhaps due to increasing obesity rates in later years.16

The prevalence of the condition among Medicare beneficiaries (people aged 65 years or older) is believed to be higher than the aforementioned estimates among middle-aged people. In the population-based Sleep Heart Health Study the prevalence of AHI≥15 events/hour was 1.7-fold higher in people older than 60 years compared to people between 40 and 60 years of age.17 Similar observations were made in cohort studies that used population-based samples and a wide range of ages.18–21 However, scant data suggest that the prevalence of OSAHS does not continue to rise with age in older adults, but reaches a plateau after the age of 60–65 years.17,22 This implies either a relative increase in mortality from OSAHS, or a remission of OSAHS with advancing age (the Methods section provides a discussion on the prevalence of OSAHS in the modeled populations).

Apart from the use of AHI, other methods to quantify severity have also been used in various studies. These mainly pertain to the evaluation of O_2_ desaturations during sleep, the evaluation of other respiratory events such as the Respiratory Effort Related Arousals, or the degree of daytime fatigue and somnolence.

The standard measurement of AHI (and the diagnosis of OSAHS by extension) requires a comprehensive, technologist-attended sleep study with multichannel polysomnography (PSG), which is performed in specialized sleep laboratories.1,14 Laboratory-based PSG records a variety of neurophysiologic and cardiorespiratory signals and is interpreted by trained technologists and sleep physicians after the sleep study has been completed. Because of the high demand, the associated costs and the need for timely diagnosis, portable devices have been developed to substitute for laboratory-based PSG.14 There are different types (classes) of portable monitors.23 Each gathers different neurophysiologic and respiratory information and may synthesize the accumulated data differently.23

Depending on the data they record, portable monitors are classified in different categories (which are briefly discussed in the Definitions and Terminology section).23 Portable monitors can be used not only in the home setting, but also in the hospital and in clinics that are not specialized sleep units.

## Management of OSAHS

The mainstay of treatment is considered to be continuous positive airway pressure (CPAP).24 Other treatments for the condition exist and are reserved for specific cases (e.g., surgical interventions and oral-dental appliances to improve the stereometry of the upper airway).

CPAP treatment of OSAHS has been associated with beneficial health outcomes. Observational evidence from prospective comparative studies associates CPAP treatment of OSAHS with fewer cardiovascular events.2,4 Furthermore, patients with OSAHS have an increased risk for car accidents.12,13 CPAP has been associated with a reduction in the risk for motor vehicle accidents among people with OSAHS.25–27.

However, apart from the aforementioned considerations there is no extensive randomized evidence on outcomes such as deaths, strokes and cardiovascular events.28 There is randomized evidence that CPAP versus no treatment or sham CPAP treatment of OSAHS is associated with improvements in the Epworth Sleepiness Scale28 (a subjective symptom score), objective wakefulness tests28 and selected components of the SF-36 questionnaire28 (e.g., the vitality component, which is more relevant to OSAHS patients compared to other SF-36 components29). Randomized studies suggest that CPAP may also be inversely associated with intermediate clinical outcomes (e.g., hypertension).28

Typically, the diagnosis of OSAHS is made after a positive comprehensive sleep study with multichannel polysomnography (PSG) in specialized sleep laboratories.1,14 For patients who meet the diagnostic criteria, a second session is needed for the titration of the CPAP device to a tolerable and effective pressure. Because of the large demand, variants of this strategy may be used. For example, in split-night studies, both the diagnostic workup and the titration of the CPAP device (when needed) may be performed at the same night: The diagnosis may be established during the first hours of the sleep study and the effect of the CPAP device is assessed by the attending technician during the last hours of the sleep study. Sleep studies may also be conducted at daytime to reduce cost. Different strategies may entail prioritizing referral cases based on clinical considerations or on the results of portable, home-based sleep monitoring. In addition, several devices can function as portable unattended sleep monitors (diagnostic mode) and auto-titrate the CPAP threshold, again in an unattended fashion.

## Statement of Work

The Center for Medicare and Medicaid Services (CMS) has requested a technology assessment through the Agency for Healthcare Research and Quality (AHRQ) on the role of home monitoring for the diagnosis of OSAHS. On September 28, 2004, the evidence on home monitoring devices in the diagnosis of sleep apnea was discussed at a Medicare Coverage Advisory Committee meeting. The RTI EPC presented a technology assessment on this topic,30 which was an update of a prior technology assessment done for the American Academy of Sleep Medicine, the American Thoracic Society, and the American College of Chest Physicians.14 CMS has requested an update of the evidence presented in the RTI EPC technology assessment on home sleep monitoring with an expanded scope, including the assessment of the ability of PSG indices to predict a response to CPAP treatment. The current project is a follow-on to the Technology Assessment “Home diagnosis of obstructive sleep apnea-hypopnea syndrome” that was prepared by the Tufts-NEMC EPC.

There are no direct comparison studies evaluating the plausible strategies for OSAHS diagnosis and initiation of CPAP treatment. In consultation with AHRQ and CMS staff we undertook an analysis of various strategies to manage patients with high clinical suspicion for OSAHS, using a Markov process-based decision tree. Markov modeling is an established decision analytic method. It is typically used to simulate comparisons when direct data are non-existent. Herein we focus on a description of the profile of different strategies in terms of accuracy of diagnosis, proportion of people started on CPAP, time to diagnosis, and time to successful CPAP titration among people who need it. We did not perform a full decision analysis (i.e., calculation of expected utilities over lifelong projections), because there are considerable uncertainties clinical outcomes such as deaths, cardiovascular events, strokes, etc. that pose great difficulties for a meaningful analysis.

## Outline of the technology assessment

The methods section describes:

1. The modeled strategies and their assumptions.
2. Which transition probabilities and other quantities are used in the models, the values used in the baseline analyses and where these were obtained from, the uncertainty that accompanies each value.

The Results section describes:

1. (Per outcome) the results of the baseline analyses.
2. (Per outcome) the results of the sensitivity analyses, which assess how each outcome is affected if one changes the values that were use in the baseline analyses over a prespecified range.