# Discussion

We used established and well-suited methods to perform mathematical modeling of the direct comparison of seven different strategies for the diagnosis of OSAHS and titration of CPAP level, which has not been done in an actual study. Our modeling approaches are based on estimates obtained from focused systematic reviews and meta-analyses of the literature. We simulated cohorts of patients suspected for OSAHS and followed them up for a time horizon of 2 years or until they had a technically adequate CPAP titration study.

The modeled populations are people with symptoms and signs suggestive of OSAHS, who are referred for further diagnostic workup. This is a subgroup of the general population of middle-aged people or older adults. Therefore, the models do not describe screening for OSAHS in the general population. The Methods section has a more detailed description of the simulated populations.

Our simulations stop at the point where people with positive diagnoses are offered CPAP treatment. Because of the uncertainty in available data, we did not model subsequent events, such as how many people actually accept the CPAP treatment, CPAP compliance and response to the intervention. Instead, we calculated the occurrence of surrogate outcomes, which have to be interpreted accordingly.

As mentioned above, the results of the modeling are based on data from the literature, and assumptions that were made for some probabilities where few or no data existed (again, see methods section for a discussion of the evidence supporting the probabilities in the baseline analyses, and the accompanying uncertainties). In addition, we did not cover any conceivable complication that arises in everyday clinical practice. There is a tradeoff between the detail with which a strategy is simulated and the parsimony of the mathematical models.

## Interpretation of outcomes

The modeling illustrates the tradeoff in the number of people with OSAHS (as defined in the Methods section) who are offered CPAP and time to diagnosis or technically adequate CPAP level titration across seven different simulated strategies. Strategies that use portable monitors as a first (or only) test generally result in shorter average time to diagnosis and technically adequate CPAP level titration, but also in increased numbers of “false positives” or “false negatives” compared to PSG (depending on the strategy). Diagnosis and CPAP level titration entirely in the sleep labs or related facilities is expected to result in better diagnostic accuracy, but may result in longer time to diagnosis and CPAP level titration.

### Proportion of people who are offered CPAP

#### Interpretation of this outcome

One may argue that it is more important to maximize the number of true positive diagnoses (i.e., maximize the sensitivity of a strategy), rather than minimize the number of false positive diagnoses (i.e., maximize the specificity of a strategy).

As mentioned in the Results (and letting aside strategies 1 and 7), in the baseline analyses strategy 2 (facility-based PSG and CPAP titration in the lab) and Strategy 5 (screening at home and further evaluation of negative cases with split-night studies) are expected to offer CPAP to almost all people with OSAHS (as defined in the current project). Management in the sleep lab with split-night studies (strategy 3) and home diagnosis of OSAHS and home CPAP titration (strategy 6) would offer CPAP to approximately 90 percent of people with OSAHS (as defined in the current project), while screening at home with portable monitors and then verification of positive cases with split-night studies would result in approximately 80 percent of people with OSAHS (as defined in the current project) being offered CPAP. These proportions were the same among older adults.

##### Maximizing true positive diagnoses

Indeed, identifying people with OSAHS and starting them on CPAP treatment is associated with positive health outcomes. Observational evidence from prospective comparative studies associates CPAP treatment of OSAHS with fewer cardiovascular events.2,4 After adjustments for potential confounders, men with untreated severe OSAHS have 2.9 higher odds (95% confidence interval: 1.2, 7.5) for fatal events and 3.2 (95% confidence interval: 1.1, 7.5) higher odds for non-fatal cardiovascular events.2

Furthermore, patients with OSAHS have an increased risk for car accidents.12,13 Assuming that CPAP treatment is effective in reducing this risk, and that patient adherence to the treatment would not diminish drastically over a short period of time, we could project that maximizing the number of true positives may have an impact in reducing accident related morbidity and mortality.

However, apart from the aforementioned considerations there is no extensive randomized evidence on outcomes such as deaths, strokes and cardiovascular events (see below a description of the relevant findings of a Cochrane Systematic Review28). There is randomized evidence that CPAP versus no treatment or sham CPAP treatment of OSAHS is associated with improvements in the Epworth Sleepiness Scale28 (a subjective symptom score), objective wakefulness tests28 and selected components of the SF-36 questionnaire28 (e.g., the vitality component, which is more relevant to OSAHS patients compared to other SF-36 components29).

Randomized evidence on whether CPAP use improves outcomes among patients with OSAHS: As mentioned above, there is evidence from randomized trials that CPAP use is associated with improvements in quality of life scores;28 however, there are no data from randomized trials on how much CPAP affects hard clinical outcomes (i.e., mortality or cardiac disease):

1. A Cochrane systematic review of randomized trials comparing CPAP with control found that CPAP use improved the Epworth Sleepiness Score (ESS) by 3.8 units on average (95% CI: 3.1, 4.6) in parallel arm trials, and approximately half of that in crossover trials.
  ESS ranges from 0 to 24, and otherwise healthy people without sleep disturbances have and average score of approximately 5.^110^ However, the minimal clinically significant difference in the ESS is not reported; therefore the clinical significance of this finding is unclear.
2. Overall, no statistically significant improvement was found for the vitality component of the Short Form 36 Questionnaire (SF36) in three small parallel arm trials with random effects analyses (but a 15 unit improvement was found with fixed effects analyses). In crossover trials, the corresponding change was 8 units (95% CI: 2, 14).28
  The vitality component of SF36 has been shown to correlate with quality of life instruments specifically developed for OSAHS.29 The lowest boundary of the 95% confidence intervals for the vitality score are lower than the minimum clinically significant difference in SF36 components, which ranges from 5 to 10 units in various diseases.111,112 Therefore, the clinical significance of this improvement is not very clear.
3. There were no data on how much CPAP affects hard clinical outcomes such as mortality, cardiovascular events, strokes, etc. The review’s conclusion was that CPAP treatment is effective in improving quality of life measures in people with moderate and severe OSAHS (similar to the ones modeled here).

##### Minimizing false positive diagnoses

Receiving a false positive diagnosis of OSAHS (and undergoing a CPAP titration study) does not result in immediate and detrimental adverse health events.

- We did not identify any adverse health events associated with a CPAP titration study in people without OSAHS. The rate and severity of adverse events in sleep studies are low. In a large prospective study of more than 16,000 lab-based PSG sessions, complications (ventricular arrhythmias) were identified in less than 0.5% of the recordings.113 (See also Section B5 in our recent Technology Assessment “Home diagnosis of obstructive sleep apnea-hypopnea syndrome”).
- We did not identify studies associating CPAP use in people without OSAHS with adverse health events.

Considerations on “false positives”: In our models, a person without OSAHS who receives a false positive diagnosis will be subjected to a CPAP titration study. We do not model the outcomes of the titration study, or decisions contingent on its results.

In people without OSAHS, it is likely that a (technically adequate) CPAP titration study will not result in a non-negligible pressure level that improves the participant’s sleep. A sleep physician may decide not to prescribe CPAP treatment in this case, despite the previous positive diagnosis. Even if CPAP treatment is prescribed, it is likely that the machine will not be used in the long term. Therefore, in “false positively” diagnosed patients CPAP may not be used at all or may be used for a relatively short period and “abandoned” thereafter. Thus, false positive diagnoses may (needlessly) increase costs. However, it is important to note that as we discussed in the previous technology assessment, there is a lack of evidence on the ability of PSG or portable monitors to predict response to CPAP and changes in clinical outcomes after CPAP treatment.

We should note that apart from inflating costs, a false positive result might also affect health adversely. Any labeling of disease that is inaccurate can have psychological implications,114 such as increased anxiety. False positive diagnoses might lead to inappropriate and ineffective treatment and/or lack of further diagnostic evaluation to find the true cause of the patient’s symptoms. This is especially true if as a result of lack of improvement to the inappropriate treatment, the patient mistrusts the medical system. The patient may also opt out of seeking further evaluation because of having spent considerable time and money on the evaluation and treatment for the inaccurate diagnosis. Finally, the treating physician may also not pursue other diagnoses feeling the patient is non-adherent to CPAP treatment or is just a “non-responder”.

### Time to final diagnosis

Time to final diagnosis is a surrogate outcome that reflects how tiring the whole diagnostic process may be for a patient, and how “efficiently” a specific strategy classifies people. During this interval certain events (e.g., having a driving accident) might occur to a patient with OSAHS; however, whether knowledge of a diagnosis would alter the likelihood of such events happening (e.g., through modification of lifestyle and habits) is unknown.

#### Interpretation of this outcome

There are no data on whether a delay in the diagnosis is associated with increased anxiety or any other similar outcome from a patient perspective. One may postulate that informing a patient on whether he has OSAHS or not might affect his or her driving behavior or lifestyle; however, this is hypothetical.

Generally, it is conceivable that strategies with shorter time-to-diagnosis have a quicker turnaround; this indicates better “efficiency” (although the accuracy of the diagnoses should also be considered). Shorter mean time to final diagnosis is generally associated with shorter mean time to CPAP treatment (see below on the interpretation of shorter time to CPAP).

Time to diagnosis is shorter in strategy 6 (~2 weeks), then strategies 4 and 5 (~5 weeks), strategy 3 (~10 weeks) and strategy 2 (~14 weeks).

### Time to CPAP among people with a positive diagnosis for OSAHS who are offered CPAP

#### Interpretation of the findings

CPAP treatment of OSAHS has been associated with beneficial health outcomes. Observational evidence from prospective comparative studies associates CPAP treatment of OSAHS with fewer cardiovascular events.2,4 Furthermore, patients with OSAHS have an increased risk for car accidents.12,13 CPAP has been associated with a reduction in the risk for motor vehicle accidents among people with OSAHS.25–27.

However, apart from the aforementioned considerations there is no extensive randomized evidence on outcomes such as deaths, strokes and cardiovascular events.28 There is randomized evidence that CPAP versus no treatment or sham CPAP treatment of OSAHS is associated with improvements in the Epworth Sleepiness Scale28 (a subjective symptom score), objective wakefulness tests28 and selected components of the SF-36 questionnaire28 (e.g., the vitality component, which is more relevant to OSAHS patients compared to other SF-36 components29). Randomized studies suggest that CPAP may also be inversely associated with intermediate clinical outcomes (e.g., hypertension).28

This outcome is very sensitive to the actual value of the average waiting time for a sleep study in the sleep labs, a quantity for which we do not have extensive data. Moreover, there is evidence that there are many differences in the average waiting times across various regions in the US, or even among hospitals.96 In the results section (sensitivity analyses) we provide results for a range of average waiting times.

For the baseline analyses, a patient in strategy 6 and strategy 4 would be offered CPAP after a period of approximately 5 weeks, and in strategy 5 after approximately 6 weeks. For strategy 3 (split-night studies in the lab) the corresponding mean delay is approximately 10 weeks and for strategy 2 (facility-based PSG and CPAP titration in different nights) it would be 27 weeks, i.e. there is on average a 22-week gap between these strategies. However, in sensitivity analyses this gap may become as low as 3 weeks. As the average waiting time for a study in the sleep lab decreases, the absolute differences across strategies 2 to 6 dissipate.

#### RCTs on delayed CPAP initiation among people with OSAHS

A randomized trial compared immediate initiation of treatment with CPAP versus a 6 month delay in treatment.115 However, the trial does not directly answer how bad a 6-month delay is: The trial did not report differences in deaths or hard clinical outcomes (e.g., cardiovascular events, mortality) during the 6-month delay (and is underpowered to make any such comparison in the first place). It concludes that the delay deprives people with severe OSAHS (AHI>30 events/hour) from a 5-point improvement in the Epworth Sleepiness Scale and a 12-point improvement in the Nottingham Health Profile quality of life instrument. Delayed treatment did not impact on cognitive function measures or in healthcare expenditure.115 It is therefore questionable whether a 6-month delay in the diagnosis or treatment affects patient well-being appreciably.

### Additional caveats

#### Indication creep

As discussed in the Methods section, widespread use of screening strategies for OSAHS may result in “indication creep” a phenomenon where the test is applied to a wider base of people, including also people with lower likelihood for OSAHS than the typical enrollee in clinical studies.

Indication creep would result in more people being evaluated. It would also result to lower OSAHS prevalence (compared to the value used in the modeling). A directly relevant consideration is that the diagnostic ability of the different monitors may vary in different patient populations (spectrum effects116). This is part of the rationale that penalized the specificity of portable monitors in the sensitivity analysis among older adults.

Indication creep might not be necessarily a bad thing – it is unknown how many patients with OSAHS are simply not recognized because they have not been referred for a diagnostic study.

#### Is AHI (or RDI) sufficient to diagnose OSAHS?

Polysomnographic indices alone (such as AHI, RDI, oxygen saturation levels, etc.) are not sufficient to classify people into those with and without OSAHS. This is because facility-based PSG and portable monitoring do not inform on aspects of OSAHS other than the measured sleep parameters. It is acknowledged that the AHI does not correlate well with the intensity of the symptoms in patients with OSAHS.14 The correlations between AHI (and other PSG indices such as arousals or desaturation variables) and daytime measures of quality of life, well-being, subjective sleepiness, symptoms and cognitive performance are weak.15 There are probably no clinical or statistical differences between patients who differ only by a few points in the AHI. Moreover, AHI is not well correlated with response to CPAP therapy, or compliance to the therapy itself, among people selected for CPAP treatment.117–124

Here we defined OSAHS as the presence of suggestive symptoms and signs (considered a given in the modeled populations) along with an AHI of more than 15 events/hour of sleep. Of course people who have AHI values less than 15 events/hour of sleep may still benefit from CPAP (or other) treatment. For example, there is no clinical reason why a patient who has an AHI of 14 events/hour in facility-based PSG would benefit less than a patient with 16 events/hour in facility-based PSG. These considerations pertain to any cutoff, and are not specific to the one used here.

#### Is AHI necessary for the management of people suspected of OSAHS?

As of this writing, no RCT were identified that compared hard clinical outcomes between people managed with facility-based PSG and with portable monitors only. However, as of this writing, there are ongoing trials that are evaluating the role of portable monitors in managing people suspected for OSAHS, compared to facility-based PSG.

We identified a recent RCT by Mulgrew 2007^108^ evaluating the utility of a diagnostic algorithm that did not involve facility-based PSG in the initial management of people suspected of OSAHS. In brief, 68 patients with high probability for AHI >15 events/hour (i.e., moderate to severe OSAHS) were selected on the basis of Epworth Sleepiness Scale score, Sleep Apnea Clinical Score and overnight oximetry that were suggestive of OSAHS. They were randomly assigned to CPAP titration guided by facility-based PSG or ambulatory CPAP auto-titration (without facility-based PSG). The latter arm used a combination of auto-CPAP and overnight oximetry.

After 3 months there were no differences between arms in the AHI on CPAP (the primary endpoint). Both arms achieved low median AHI on CPAP at three months (median 3.2 versus 2.5 events/hour in the arms that used and did not use facility-based PSG, respectively). Furthermore, no differences beyond chance were found for the secondary outcomes of the RCT. The difference in the change from baseline in the Epworth Sleepiness Scale score was 1 (p=0.26 for the between-arm comparison). The corresponding difference for the Sleep Apnea Quality of Life Index was 0.17 (p=0.69 for the between-arm comparison) (the minimum clinically significant difference is 1 unit in this score29,125). Scores for both aforementioned secondary outcomes improved in almost all patients compared to baseline. Finally, adherence to CPAP was higher (p=0.021) in the arm that did not receive facility-based PSG (median CPAP use, 6.0 hours/night [interquartile range: 5.1, 7.1]) compared to the arm that received facility-based PSG (median use, 5.4 hours/night [interquartile range: 3.7, 6.4]).

The RCT concluded that in the initial management of patients with high probability of OSAHS, PSG testing confers no advantage over an ambulatory approach in terms of diagnosis and CPAP titration. There was also evidence that adherence might be better with the ambulatory approach.

### Limitations

There are several limitations in the approach we used here.

First, the scenarios that have been modeled are only a simplified version of the actual strategies. There are many additional possibilities that have not been modeled; for example no deaths or crossover between different strategies are allowed, and co-morbidities have not been taken into account. There is a tradeoff between model parsimony and fidelity in the simulation of the real world. The analyst has to keep a balance between a model that is simple enough to implement, but comprehensive enough to capture all interesting phenomena that are expected to occur. We believe that the structure of the simulated strategies achieves the desirable balance.

Furthermore, some transition probability estimates are based on relatively sparse data. We refer the reader to the corresponding paragraphs in the Methods section for a detailed discussion of the sources of the transition probabilities we used, as well as the accompanying uncertainty. For example, the average waiting time for a sleep study in the lab is a key quantity that influences greatly the results for the time to diagnosis and time to CPAP. As described in the Methods, we have addressed the uncertainty that accompanies each estimate with sensitivity analyses.

Similarly, the estimates for the older adults are based on extrapolations of data that pertain to middle-aged people and on calculations that we considered plausible. There are simply no data specific to the age group that corresponds to Medicare beneficiaries for the transition probabilities used in our model. This is an obvious gap in the existing published literature. Apart from conducting new studies among older adults, analyzing the subgroup of older patients in existing datasets may provide useful information. We conducted wide-ranged sensitivity analyses in the models to help address uncertainty in some probabilities among older adults.