# Table of eligible studies

The following citations have been deemed eligible after full text review. They are listed in alphabetical order (by first author’s surname).

Appendix Table Citations of included publications

Citation | PMID
Adachi, H., Mikami, A., Kumano-go, T., Suganuma, N., Matsumoto, H., Shigedo, Y., Sugita, Y., and Takeda, M. Clinical significance of pulse rate rise during sleep as a screening marker for the assessment of sleep fragmentation in sleep-disordered breathing.[see comment]. Sleep Medicine 2003. 4 (6):537–542. | 14607348
Alvarez, D., Hornero, R., Abasolo, D., del, Campo F., and Zamarron, C. Nonlinear characteristics of blood oxygen saturation from nocturnal oximetry for obstructive sleep apnoea detection. Physiological Measurement 2006. 27 (4):399–412. | 16537981
Ancoli-Israel, S., Mason, W., Coy, T. V., Stepnowsky, C., Clausen, J. L., and Dimsdale, J. Evaluation of sleep disordered breathing with unattended recording: the Nightwatch System. Journal of Medical Engineering & Technology 1997. 21 (1):10–14. | 9080356
Ayappa, I., Norman, R. G., Suryadevara, M., and Rapoport, D. M. Comparison of limited monitoring using a nasal-cannula flow signal to full polysomnography in sleep-disordered breathing. Sleep 2004. 27 (6):1171–1179. | 15532212
Ayas, N. T., Pittman, S., MacDonald, M., and White, D. P. Assessment of a wrist-worn device in the detection of obstructive sleep apnea. Sleep Medicine 2003. 4 (5):435–442. | 14592285
Bagnato, M. C., Nery, L. E., Moura, S. M., Bittencourt, L. R., and Tufik, S. Comparison of AutoSet and polysomnography for the detection of apnea-hypopnea events. Brazilian Journal of Medical & Biological Research 2000. 33 (5):515–519. | 10775882
Ballester, E., Solans, M., Vila, X., Hernandez, L., Quinto, L., Bolivar, I., Bardagi, S., and Montserrat, J. M. Evaluation of a portable respiratory recording device for detecting apnoeas and hypopnoeas in subjects from a general population. European Respiratory Journal 2000. 16 (1):123–127. | 10933097
Baltzan, M. A., Verschelden, P., Al-Jahdali, H., Olha, A. E., and Kimoff, R. J. Accuracy of oximetry with thermistor (OxiFlow) for diagnosis of obstructive sleep apnea and hypopnea. Sleep 2000. 23 (1):61–69. | 10678466
Bar, A., Pillar, G., Dvir, I., Sheffy, J., Schnall, R. P., and Lavie, P. Evaluation of a portable device based on peripheral arterial tone for unattended home sleep studies.[see comment]. Chest 2003. 123 (3):695–703. | 12628865
Bearpark, H., Elliott, L., Grunstein, R., Cullen, S., Schneider, H., Althaus, W., and Sullivan, C. Snoring and sleep apnea. A population study in Australian men. American Journal of Respiratory & Critical Care Medicine 1995. 151 (5):1459–1465. | 7735600
Bednarek, M., Plywaczewski, R., Jonczak, L., and Zielinski, J. There is no relationship between chronic obstructive pulmonary disease and obstructive sleep apnea syndrome: a population study. Respiration 2005. 72(2):142–149. | 15824523
Bonsignore, G., Marrone, O., Macaluso, C., Salvaggio, A., Stallone, A., and Bellia, V. Validation of oximetry as a screening test for obstructive sleep apnoea syndrome. European Respiratory Journal - Supplement 1990. 11:542s-544s. | 2278624
Bradley, P. A., Mortimore, I. L., and Douglas, N. J. Comparison of polysomnography with ResCare Autoset in the diagnosis of the sleep apnoea/hypopnoea syndrome. Thorax 1995. 50 (11):1201–1203. | 8553279
Calleja, J. M., Esnaola, S., Rubio, R., and Duran, J. Comparison of a cardiorespiratory device versus polysomnography for diagnosis of sleep apnoea. European Respiratory Journal 2002. 20 (6):1505–1510. | 12503711
Carrasco, O., Montserrat, J. M., Lloberes, P., Ascasco, C., Ballester, E., Fornas, C., and Rodriguez-Roisin, R. Visual and different automatic scoring profiles of respiratory variables in the diagnosis of sleep apnoea-hypopnoea syndrome. European Respiratory Journal 1996. 9 (1):125–130. | 8834345
Chiner, E., Signes-Costa, J., Arriero, J. M., Marco, J., Fuentes, I., and Sergado, A. Nocturnal oximetry for the diagnosis of the sleep apnoea hypopnoea syndrome: a method to reduce the number of polysomnographies?[see comment]. Thorax 1999. 54 (11):968–971. | 10525553
Chung, K. F. Half-night polysomnography: how is it compared to full-night polysomnography? Eur Respir J 1998. 12 (3):749–749. | 9762809
Claman D, Murr A, Trotter K. Clinical validation of the Bedbugg in detection of obstructive sleep apnea. Otolaryngol Head Neck Surg 2001; 125(3):227–230. | 11555758
Cooper, B. G., Veale, D., Griffiths, C. J., and Gibson, G. J. Value of nocturnal oxygen saturation as a screening test for sleep apnoea. Thorax 1991. 46 (8):586–588. | 1926029
Dingli, K., Coleman, E. L., Vennelle, M., Finch, S. P., Wraith, P. K., Mackay, T. W., and Douglas, N. J. Evaluation of a portable device for diagnosing the sleep apnoea/hypopnoea syndrome. European Respiratory Journal 2003. 21 (2):253–259. | 12608438
Douglas, N. J., Thomas, S., and Jan, M. A. Clinical value of polysomnography.[see comment]. Lancet 1992. 339 (8789):347–350. | 1346422
Emsellem, H. A., Corson, W. A., Rappaport, B. A., Hackett, S., Smith, L. G., and Hausfeld, J. N. Verification of sleep apnea using a portable sleep apnea screening device. Southern Medical Journal 1990. 83 (7):748–752. | 2371595
Esnaola, S., Duran, J., Infante-Rivard, C., Rubio, R., and Fernandez, A. Diagnostic accuracy of a portable recording device (MESAM IV) in suspected obstructive sleep apnoea. European Respiratory Journal 1996. 9 (12):2597–2605. | 8980975
Fanfulla, F., Patruno, V., Bruschi, C., and Rampulla, C. Obstructive sleep apnoea syndrome: is the "half-night polysomnography" an adequate method for evaluating sleep profile and respiratory events? Eur Respir J 1997. 10 (8):1725–1729. | 9272910
Ficker JH, Wiest GH, Wilpert J, Fuchs FS, Hahn EG. Evaluation of a portable recording device (Somnocheck) for use in patients with suspected obstructive sleep apnoea. Respiration 2001; 68(3):307–312. | 11416253
Fietze, I., Glos, M., Rottig, J., and Witt, C. Automated analysis of data is inferior to visual analysis of ambulatory sleep apnea monitoring. Respiration 2002. 69 (3):235–241. | 12097767
Flemons, W. W., Whitelaw, W. A., Brant, R., and Remmers, J. E. Likelihood ratios for a sleep apnea clinical prediction rule. American Journal of Respiratory & Critical Care Medicine 1994. 150 (5:Pt 1):t-85. | 7952553
Flemons, W.W., Douglas, N.J., Kuna, S.T., Rodenstein, D.O., and Wheatley, J. Access to diagnosis and treatment of patients with suspected sleep apnea. Am J Respir Crit Care Med 2004. 169 (6):668–672. | 15003950
Fletcher, E. C., Stich, J., and Yang, K. L. Unattended home diagnosis and treatment of obstructive sleep apnea without polysomnography. Archives Fam Med 2000. 9 (2):168–174. | 10693735
Fleury, B., Rakotonanahary, D., Hausser-Hauw, C., Lebeau, B., and Guilleminault, C. A laboratory validation study of the diagnostic mode of the Autoset system for sleep-related respiratory disorders. Sleep 1996. 19 (6):502–505. | 8865509
Fry, J. M., DiPhillipo, M. A., Curran, K., Goldberg, R., and Baran, A. S. Full polysomnography in the home. Sleep 1998. 21 (6):635–642. | 9779523
Gagnadoux, F., Pelletier-Fleury, N., Philippe, C., Rakotonanahary, D., and Fleury, B. Home unattended vs hospital telemonitored polysomnography in suspected obstructive sleep apnea syndrome: a randomized crossover trial. Chest 2002. 121 (3):753–758. | 11888956
Golpe, R., Jimenez, A., and Carpizo, R. Home sleep studies in the assessment of sleep apnea/hypopnea syndrome. Chest 2002. 122 (4):1156–1161. | 12377836
Gugger, M. Comparison of ResMed AutoSet (version 3.03) with polysomnography in the diagnosis of the sleep apnoea/hypopnoea syndrome. European Respiratory Journal 1997. 10 (3):587–591. | 9072989
Gugger, M., Mathis, J., and Bassetti, C. Accuracy of an intelligent CPAP machine with in-built diagnostic abilities in detecting apnoeas: a comparison with polysomnography. Thorax 1995. 50 (11):1199–1201. | 8553278
Gurubhagavatula, I., Maislin, G., Nkwuo, J. E., and Pack, A. I. Occupational screening for obstructive sleep apnea in commercial drivers. American Journal of Respiratory & Critical Care Medicine 2004. 170 (4):371–376. | 15142866
Gyulay, S., Gould, D., Sawyer, B., Pond, D., Mant, A., and Saunders, N. Evaluation of a microprocessor-based portable home monitoring system to measure breathing during sleep. Sleep 1987. 10 (2):130–142. | 3589326
Hedner, J., Pillar, G., Pittman, S. D., Zou, D., Grote, L., and White, D. P. A novel adaptive wrist actigraphy algorithm for sleep-wake assessment in sleep apnea patients. Sleep 2004. 27 (8):1560–1566. | 15683148
Ip, M. S., Lam, B., Tang, L. C., Lauder, I. J., Ip, T. Y., and Lam, W. K. A community study of sleep-disordered breathing in middle-aged Chinese women in Hong Kong: prevalence and gender differences. Chest 2004. 125 (1):127–134. | 14718431
Issa, F. G., Morrison, D., Hadjuk, E., Iyer, A., Feroah, T., and Remmers, J. E. Digital monitoring of sleep-disordered breathing using snoring sound and arterial oxygen saturation. American Review of Respiratory Disease 1993. 148 (4:Pt 1):t-9. | 8214920
Kapur, V. K., Rapoport, D. M., Sanders, M. H., Enright, P., Hill, J., Iber, C., and Romaniuk, J. Rates of sensor loss in unattended home polysomnography: the influence of age, gender, obesity, and sleep-disordered breathing. Sleep 2000. 23 (5):682–688. | 10947036
Kiely, J. L., Delahunty, C., Matthews, S., and McNicholas, W. T. Comparison of a limited computerized diagnostic system (ResCare Autoset) with polysomnography in the diagnosis of obstructive sleep apnoea syndrome. European Respiratory Journal 1996. 9 (11):2360–2364. | 8947086
Koziej, M., Cieslicki, J. K., Gorzelak, K., Sliwinski, P., and Zielinski, J. Hand-scoring of MESAM 4 recordings is more accurate than automatic analysis in screening for obstructive sleep apnoea. European Respiratory Journal 1994. 7 (10):1771–1775. | 7828683
Levy, P., Pepin, J. L., schaux-Blanc, C., Paramelle, B., and Brambilla, C. Accuracy of oximetry for detection of respiratory disturbances in sleep apnea syndrome. Chest 1996. 109 (2):395–399. | 8620711
Lloberes, P., Montserrat, J. M., Ascaso, A., Parra, O., Granados, A., Alonso, P., Vilaseca, I., and Rodriguez-Roisin, R. Comparison of partially attended night time respiratory recordings and full polysomnography in patients with suspected sleep apnoea/hypopnoea syndrome. Thorax 1996. 51 (10):1043–1047. | 8977607
Man, G. C. and Kang, B. V. Validation of a portable sleep apnea monitoring device. Chest 1995. 108 (2):388–393. | 7634872
Margel, D., Cohen, M., Livne, P. M., and Pillar, G. Severe, but not mild, obstructive sleep apnea syndrome is associated with erectile dysfunction. Urology 2004. 63 (3):545–549. | 15028455
Marrone, O., Salvaggio, A., Insalaco, G., Bonsignore, M. R., and Bonsignore, G. Evaluation of the POLYMESAM system in the diagnosis of obstructive sleep apnea syndrome. Monaldi Archives for Chest Disease 2001. 56 (6):486–490. | 11980277
Masa, J. F., Rubio, M., and Findley, L. J. Habitually sleepy drivers have a high frequency of automobile crashes associated with respiratory disorders during sleep. American Journal of Respiratory & Critical Care Medicine 2000. 162 (4:Pt 1):t-12. | 11029353
Mayer, P., Meurice, J. C., Philip-Joet, F., Cornette, A., Rakotonanahary, D., Meslier, N., Pepin, J. L., Levy, P., and Veale, D. Simultaneous laboratory-based comparison of ResMed Autoset with polysomnography in the diagnosis of sleep apnoea/hypopnoea syndrome. European Respiratory Journal 1998. 12 (4):770–775. | 9817143
Michaelson, P. G., Allan, P., Chaney, J., Mair, E. A. Validations of a portable home sleep study with twelve-lead polysomnography: comparisons and insights into a variable gold standard. Annals of Otology, Rhinology & Laryngology 2006; 115 (11):802–809. | 17165661
Middelkoop, H. A., Knuistingh, Neven A., van Hilten, J. J., Ruwhof, C. W., and Kamphuisen, H. A. Wrist actigraphic assessment of sleep in 116 community based subjects suspected of obstructive sleep apnoea syndrome. Thorax 1995. 50 (3):284–289. | 7660344
Mykytyn, I. J., Sajkov, D., Neill, A. M., and McEvoy, R. D. Portable computerized polysomnography in attended and unattended settings. Chest 1999. 115 (1):114–122. | 9925071
Neven, A. K., Middelkoop, H. A., Kemp, B., Kamphuisen, H. A., and Springer, M. P. The prevalence of clinically significant sleep apnoea syndrome in The Netherlands. Thorax 1998. 53 (8):638–642. | 9828848
Overland, B., Bruskeland, G., Akre, H., and Skatvedt, O. Evaluation of a portable recording device (Reggie) with actimeter and nasopharyngeal/esophagus catheter incorporated. Respiration 2005. 72 (6):600–605. | 15988172
Pang, K. P., Dillard, T. A., Blanchard, A. R., Gourin, C. G., Podolsky, R., and Terris, D. J. A comparison of polysomnography and the SleepStrip in the diagnosis of OSA. Otolaryngology - Head & Neck Surgery 2006; 135 (2):265–268. | 16890080
Parra, O., Garcia-Esclasans, N., Montserrat, J. M., Garcia, Eroles L., Ruiz, J., Lopez, J. A., Guerra, J. M., and Sopena, J. J. Should patients with sleep apnoea/hypopnoea syndrome be diagnosed and managed on the basis of home sleep studies?[see comment]. European Respiratory Journal 1997. 10 (8):1720–1724. | 9272909
Penzel, T., Kesper, K., Pinnow, I., Becker, H. F., and Vogelmeier, C. Peripheral arterial tonometry, oximetry and actigraphy for ambulatory recording of sleep apnea. Physiological Measurement 2004. 25 (4):1025–1036. | 15382839
Pepin, J. L., Levy, P., Lepaulle, B., Brambilla, C., and Guilleminault, C. Does oximetry contribute to the detection of apneic events? Mathematical processing of the SaO2 signal. Chest 1991. 99 (5):1151–1157. | 2019170
Pillar, G., Bar, A., Betito, M., Schnall, R. P., Dvir, I., Sheffy, J., and Lavie, P. An automatic ambulatory device for detection of AASM defined arousals from sleep: the WP100. Sleep Medicine 2003. 4 (3):207–212. | 14592323
Pittman, S. D., Ayas, N. T., MacDonald, M. M., Malhotra, A., Fogel, R. B., and White, D. P. Using a wrist-worn device based on peripheral arterial tonometry to diagnose obstructive sleep apnea: in-laboratory and ambulatory validation. Sleep 2004. 27 (5):923–933. | 15453551
Pittman, S. D., MacDonald, M. M., Fogel, R. B., Malhotra, A., Todros, K., Levy, B., Geva, A. B., and White, D. P. Assessment of automated scoring of polysomnographic recordings in a population with suspected sleep-disordered breathing. Sleep 2004. 27 (7):1394–1403. | 15586793
Portier, F., Portmann, A., Czernichow, P., Vascaut, L., Devin, E., Benhamou, D., Cuvelier, A., and Muir, J. F. Evaluation of home versus laboratory polysomnography in the diagnosis of sleep apnea syndrome. American Journal of Respiratory & Critical Care Medicine 2000. 162 (3:Pt 1):t-8. | 10988088
Quintana-Gallego, E., Villa-Gil, M., Carmona-Bernal, C., Botebol-Benhamou, G., Martinez-Martinez, A., Sanchez-Armengol, A., Polo-Padillo, J., and Capote, F. Home respiratory polygraphy for diagnosis of sleep-disordered breathing in heart failure. European Respiratory Journal 2004. 24 (3):443–448. | 15358704
Rauscher, H., Popp, W., and Zwick, H. Quantification of sleep disordered breathing by computerized analysis of oximetry, heart rate and snoring. European Respiratory Journal 1991. 4 (6):655–659. | 1889491
Rauscher, H., Popp, W., and Zwick, H. Model for investigating snorers with suspected sleep apnoea. Thorax 1993. 48 (3):275–279. | 8497828
Redline, S., Tosteson, T., Boucher, M. A., and Millman, R. P. Measurement of sleep-related breathing disturbances in epidemiologic studies. Assessment of the validity and reproducibility of a portable monitoring device. Chest 1991. 100 (5):1281–1286. | 1935282
Rees, K., Wraith, P. K., Berthon-Jones, M., and Douglas, N. J. Detection of apnoeas, hypopnoeas and arousals by the AutoSet in the sleep apnoea/hypopnoea syndrome. European Respiratory Journal 1998. 12 (4):764–769. | 9817142
Reichert, J. A., Bloch, D. A., Cundiff, E., and Votteri, B. A. Comparison of the NovaSom QSG, a new sleep apnea home-diagnostic system, and polysomnography. Sleep Medicine 2003. 4 (3):213–218. | 14592324
Ryan, P. J., Hilton, M. F., Boldy, D. A., Evans, A., Bradbury, S., Sapiano, S., Prowse, K., and Cayton, R. M. Validation of British Thoracic Society guidelines for the diagnosis of the sleep apnoea/hypopnoea syndrome: can polysomnography be avoided? Thorax 1995. 50 (9):972–975. | 8539678
Sanders, M. H., Black, J., Costantino, J. P., Kern, N., Studnicki, K., and Coates, J. Diagnosis of sleep-disordered breathing by half-night polysomnography. Am Rev Respir Dis 1991. 144 (6): 1256–1261. | 1741536
Schafer, H., Ewig, S., Hasper, E., and Luderitz, B. Predictive diagnostic value of clinical assessment and nonlaboratory monitoring system recordings in patients with symptoms suggestive of obstructive sleep apnea syndrome. Respiration 1997. 64 (3):194–199. | 9154670
Series, F. and Marc, I. Nasal pressure recording in the diagnosis of sleep apnoea hypopnoea syndrome.[see comment]. Thorax 1999. 54 (6):506–510. | 10335004
Series, F., Marc, I., Cormier, Y., and La, Forge J. Utility of nocturnal home oximetry for case finding in patients with suspected sleep apnea hypopnea syndrome.[see comment]. Annals of Internal Medicine 1993. 119 (6):449–453. | 8357109
Shochat, T., Hadas, N., Kerkhofs, M., Herchuelz, A., Penzel, T., Peter, J. H., and Lavie, P. The SleepStrip: an apnoea screener for the early detection of sleep apnoea syndrome. European Respiratory Journal 2002. 19 (1):121–126. | 11843310
Stoohs, R. and Guilleminault, C. MESAM 4: an ambulatory device for the detection of patients at risk for obstructive sleep apnea syndrome (OSAS). Chest 1992. 101 (5):1221–1227. | 1582275
Su, S., Baroody, F. M., Kohrman, M., and Suskind, D. A comparison of polysomnography and a portable home sleep study in the diagnosis of obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery 2004. 131 (6):844–850. | 15577778
Van Surell C., Lemaigre, D., Leroy, M., Foucher, A., Hagenmuller, M. P., and Raffestin, B. Evaluation of an ambulatory device, CID 102, in the diagnosis of obstructive sleep apnoea syndrome. European Respiratory Journal 1995. 8 (5):795–800. | 7656952
Vazquez, J. C., Tsai, W. H., Flemons, W. W., Masuda, A., Brant, R., Hajduk, E., Whitelaw, W. A., and Remmers, J. E. Automated analysis of digital oximetry in the diagnosis of obstructive sleep apnoea. Thorax 2000. 55 (4):302–307. | 10722770
Verse, T., Pirsig, W., Junge-Hulsing, B., and Kroker, B. Validation of the POLY-MESAM seven-channel ambulatory recording unit. Chest 2000. 117 (6):1613–1618. | 10858392
Westbrook, P. R., Levendowski, D. J., Cvetinovic, M., Zavora, T., Velimirovic, V., Henninger, D., and Nicholson, D. Description and validation of the apnea risk evaluation system: a novel method to diagnose sleep apnea-hypopnea in the home. Chest 2005. 128 (4):2166–2175. | 16236870
White, D. P., Gibb, T. J., Wall, J. M., and Westbrook, P. R. Assessment of accuracy and analysis time of a novel device to monitor sleep and breathing in the home.[see comment]. Sleep 1995. 18 (2):115–126. | 7792491
Whittle, A. T., Finch, S. P., Mortimore, I. L., Mackay, T. W., and Douglas, N. J. Use of home sleep studies for diagnosis of the sleep apnoea/hypopnoea syndrome. Thorax 1997. 52 (12):1068–1073. | 9516901
Williams, A. J., Yu, G., Santiago, S., and Stein, M. Screening for sleep apnea using pulse oximetry and a clinical score. Chest 1991. 100 (3):631–635. | 1889245
Wiltshire, N., Kendrick, A. H., and Catterall, J. R. Home oximetry studies for diagnosis of sleep apnea/hypopnea syndrome: limitation of memory storage capabilities. Chest 2001. 120 (2):384–389. | 11502633
Yin, M., Miyazaki, S., and Ishikawa, K. Evaluation of type 3 portable monitoring in unattended home setting for suspected sleep apnea: factors that may affect its accuracy. Otolaryngology - Head & Neck Surgery 2006. 134 (2):204–209. | 16455365
Zamarron, C., Gude, F., Barcala, J., Rodriguez, J. R., and Romero, P. V. Utility of oxygen saturation and heart rate spectral analysis obtained from pulse oximetric recordings in the diagnosis of sleep apnea syndrome. Chest 2003. 123 (5):1567–1576. | 12740275
Zamarron, C., Romero, P. V., Rodriguez, J. R., and Gude, F. Oximetry spectral analysis in the diagnosis of obstructive sleep apnoea. Clinical Science 1999. 97 (4):467–473. | 10491347
Zucconi, M., Ferini-Strambi, L., Castronovo, V., Oldani, A., and Smirne, S. An unattended device for sleep-related breathing disorders: validation study in suspected obstructive sleep apnoea syndrome. European Respiratory Journal 1996. 9 (6):1251–1256. | 8804946