# Calculating the average waiting time for a sleep study

This appendix shows how one calculate the mean waiting time for a sleep study the lab in strategies 3, 4 and 5 (see text for a description of the various strategies) if one knows the corresponding mean waiting time in strategy 2.

More specifically:

The mean waiting time for a sleep study with different strategies will vary. The capacity of the sleep labs (i.e., the number of sleep studies they can perform in a certain time period) is fixed. However, in different strategies the total number of sleep studies differs, and this results in different workload for the sleep labs.

## Sleep lab kinetics

Assuming a fixed capacity for sleep labs means that every week a given number of sleep studies can be performed. We call C the number of sleep studies that can be performed in a time cycle (a week).

Let N_0_^Str 2^ be the total number of sleep studies (either diagnostic or for CPAP level titration) that will be performed for the hypothetical cohort of 100,000 people in strategy 2. A single person may receive more than one sleep study in strategy 2 (i.e., after a positive diagnostic study one would receive at least one CPAP level titration study).

At each time point t (weeks) the number of remaining sleep studies is

N_t_^Str 2^ = { N_0_^Str 2^ − C · t , 0 < t ≤ (N_0_^Str 2^)/(C) 0 , t > (N_0_^Str 2^)/(C) (1)

In Equation (1) the rate at which the (unperformed) sleep studies decrease is:

(d N_t_^Str 2^)/(d t) = − C (2)

for appropriate values of t.

Equations (1) and (2) describe the kinetics of the sleep labs. Namely, the kinetics of the sleep labs follows a “zero-order” law (i.e., a linear decrease). Because the capacity of the sleep labs is fixed, the rate will always be −C in all strategies that utilize sleep labs.

## Average waiting time for a sleep study in the lab setting

From Equation (1) it follows that all sleep studies will have been performed within time T_max_^Str 2^ :

T_max_^Str 2^ = (N_0_^Str 2^)/(C) (3)

For “zero-order” kinetics, the distribution of waiting times for a sleep study is uniform between 0 and T_max_^Str 2^ . Therefore, the mean waiting time per sleep study in strategy 2 is:

T¯^Str 2^ = (T_max_^Str 2^)/(2) = (N_0_^Str 2^)/(2 C) (4)

This quantity is known from the literature search. As mentioned in the text of the technology assessment the mean waiting time was set to 13 weeks for a sleep study in the lab setting.

Following similar rationale, the mean waiting time per sleep study in the lab in strategy 3 or 4 (the other strategies that use sleep labs in the management of people suspected for OSAHS) would be (e.g., for strategy 3):

T¯^Str 3^ = (N_0_^Str 3^)/(2 C) (5)

From equations (4) and (5) we can estimate the mean waiting time in strategy 3

T¯^Str 3^ = (N_0_^Str 3^)/(N_0_^Str 2^) · T¯^Str 2^ (6)

and similarly for strategies 4 and 5:

T¯^Str 4^ = (N_0_^Str 4^)/(N_0_^Str 2^) · T¯^Str 2^ (7)

T¯^Str 5^ = (N_0_^Str 5^)/(N_0_^Str 2^) · T¯^Str 2^ (8)

Therefore, as long as we count how many sleep lab studies are expected in strategies 2, 3, 4 and 5 for 100,000 people, we can estimate the mean waiting time in strategies 3, 4 and 5 based on the mean waiting time in strategy 2.