# Modeling details for the different strategies

This Appendix provides the actual architecture of the modeled strategies, using a “decision tree” layout. It consists of a series of figures that show the possible health states and the corresponding transition probabilities. The values of the transition probabilities, the range of the corresponding sensitivity analyses, and a discussion of the different assumptions are provided in the main text of this technology assessment.

A brief description of the strategies is the following:

- Strategy 1 (“None on CPAP). None in the hypothetical cohort will ever be tested for OSAHS or offered CPAP treatment. This is one extreme scenario that has been included for comparison.
- Strategy 2 (“DxPSG, TxPSG”). All people in the hypothetical cohort will receive a diagnostic session (DxPSG) in the sleep laboratory. If the exam is positive, a second session for CPAP level titration will be scheduled.
- Strategy 3 (“Split-Night PSG”). All people in the hypothetical cohort will be assessed with split-night studies in the sleep lab. If the first half of the exam is positive, the second half is used to titrate the CPAP level. If the first half of the exam is negative no CPAP titration is attempted.
- Strategy 4 (“HomeDx, SpNPSG(+)”). All people in the hypothetical cohort will be assessed in the home setting with portable sleep monitors (HomeDx). Those with positive diagnoses (indexed by the “+” sign in the name of the strategy) will be subjected to split-night studies in the sleep laboratory, to verify the diagnosis and to titrate CPAP level (if applicable). This is a combination of strategies 3 and 6 (see below).
- Strategy 5 (“HomeDx, SpNPSG(−)”). This is similar to Strategy 4 in structure, but here people with positive diagnoses in the home setting are offered CPAP level titration, and people with negative diagnoses in the home setting will be re-evaluated with split-night studies in the lab (to minimize the number of people with OSAHS who have been missed as false negatives).
- Strategy 6 (“HomeDx, autoCPAP”). The whole hypothetical cohort is managed entirely outside the sleep laboratory. Portable monitoring in the home setting (“HomeDx”) is used for the diagnosis, and auto-titration of CPAP is attempted again in the home setting on a different night.
- Strategy 7 (“All on CPAP”). The whole cohort will be offered CPAP treatment (with auto-titration or empirical titration of the pressure level). In this scenario none is tested for OSAHS. This is the other extreme scenario that has been included for comparison.

Figure A1 Overview of the 7 strategies

Figure A1: Overview of the 7 strategies

Figure A2 Strategy 2 (DxPSG, TxPSG), people with OSAHS

Figure A2: Strategy 2 (DxPSG, TxPSG), people with OSAHS

Figure A3 Strategy 2 (DxPSG, TxPSG), people without OSAHS

Figure A3: Strategy 2 (DxPSG, TxPSG), people without OSAHS

Figure A4 Strategy 3 (Split-Night PSG), people with OSAHS

Figure A4: Strategy 3 (Split-Night PSG), people with OSAHS

Figure A5 Strategy 3 (Split-Night PSG), people without OSAHS

Figure A5: Strategy 3 (Split-Night PSG), people without OSAHS

Figure A6 Strategy 4 (HomeDx, SpNPSG(+)), people with OSAHS

Figure A6: Strategy 4 (HomeDx, SpNPSG(+)), people with OSAHS

Figure A7 Strategy 4 (HomeDx, SpNPSG(+)), people without OSAHS

Figure A6: Strategy 4 (HomeDx, SpNPSG(+)), people with OSAHS

Figure A8 Strategy 5 (HomeDx, SpNPSG(−)), people with OSAHS

Figure A8: Strategy 5 (HomeDx, SpNPSG(−)), people with OSAHS

Figure A9 Strategy 5 (HomeDx, SpNPSG(−)), people without OSAHS

Figure A9: Strategy 5 (HomeDx, SpNPSG(−)), people without OSAHS

Figure A10 Strategy 6 (HomeDx, autoCPAP), people with OSAHS

Figure A10: Strategy 6 (HomeDx, autoCPAP), people with OSAHS

Figure A11 Strategy 6 (HomeDx, autoCPAP), people without OSAHS

Figure A11: Strategy 6 (HomeDx, autoCPAP), people without OSAHS