# Summary

Obstructive Sleep Apnea-Hypopnea Syndrome (OSAHS) is characterized by sleep disturbances secondary to upper airway obstruction. OSAHS is prevalent in two to four percent of middle-aged adults, and has been associated with daytime somnolence, cardiovascular morbidity, diabetes and other metabolic abnormalities, and increased likelihood of accidents and other adverse outcomes. The prevalence of OSAHS in older adults (65 years or older) in the general population is believed to be higher than the aforementioned estimates, but it is not as well studied.

Typically, the diagnosis is set in the presence of suggestive symptoms and signs (e.g., day somnolence, fatigability) in association with sleep disturbances. We emphasize that there is no error-free “gold standard” for the diagnosis of OSAHS. However, many clinicians (and most studies) consider facility-based polysomnography (PSG) as a reference standard for quantifying sleep-related parameters that are useful in the diagnosis of OSAHS. PSG is a comprehensive sleep study that records and evaluates a variety of cardiorespiratory and neurophysiologic signals during sleep time, and takes place in a specialized clinic or laboratory. Portable monitors have also been developed for the diagnosis of OSAHS. They generally record and evaluate fewer signals compared to facility-based PSG, but they may be used in the home setting. They may constitute an alternative for the more costly facility-based PSG.

For people with positive diagnosis after a sleep study, the mainstay of treatment is considered to be continuous positive airway pressure (CPAP). CPAP has been shown to improve quality of life and symptoms of OSAHS (e.g., day-time somnolence, and fatigue). In addition, CPAP use might decrease the OSAHS-associated risk for cardiovascular outcomes (e.g., cardiac disease, stroke) or the risk for motor vehicle accidents among people with OSAHS.

No studies in the literature compared directly several different strategies to diagnose OSAHS and perform CPAP level titration in people with positive diagnoses. To compare multiple different strategies simultaneously, it is necessary to use Markov models. This is an established decision analytic approach to simulate head to head comparison of multiple strategies under various assumptions. We performed a mathematical simulation of seven different strategies that may be considered for the diagnosis of OSAHS (and the subsequent initiation of CPAP) for people who are suspected of OSAHS on the basis of suggestive symptoms and signs.

As stated above, the simulations are based on Markov processes. They assess different strategies with respect to the proportion of people who will be offered CPAP; time to final diagnosis; and time to successful titration of CPAP level among people with OSAHS who are offered CPAP.

In the simulations we defined OSAHS as presence of suggestive symptoms and signs along with an apnea-hypopnea index of at least 15 events/hour of sleep in facility-based PSG. The probabilities used in the Markov processes are derived from the literature, using meta-analysis when needed. For all transition probabilities in the mathematical models, available data from the literature pertained to middle aged people without significant comorbidities.

Because data on older people were not available, we made several assumptions on the corresponding probabilities among older people. Different analyses were performed for hypothetical cohorts of middle-aged 50-year old people and for older adults (70 years of age).

We also performed sensitivity analyses to evaluate the impact of the various probabilities on the examined outcomes. In sensitivity analyses, the value of each probability is ranged over a pre-specified range. More uncertain estimates (i.e., those based on few literature data, poor quality data or are assumptions in the absence of data) are varied over a wider range in the sensitivity analyses.

The current model is not a full decision analysis that incorporates utilities associated with different health states, but a calculation of the expected likelihood for the aforementioned outcomes. Because no costs or utilities were assigned, it is difficult to specify which is the single preferred or the most cost-effective strategy.

The following is a brief description of the modeled strategies:

- Strategy 1 (“None on CPAP). None in the hypothetical cohort will ever be tested for OSAHS or offered CPAP treatment. This is one extreme scenario that has been included for comparison.
- Strategy 2 (“DxPSG, TxPSG”). All people in the hypothetical cohort will receive a diagnostic session (DxPSG) in the sleep laboratory. If the exam is positive, a second session for CPAP level titration will be scheduled.
- Strategy 3 (“Split-Night PSG”). All people in the hypothetical cohort will be assessed with split-night studies in the sleep lab. If the first half of the exam is positive, the second half is used to titrate the CPAP level. If the first half of the exam is negative no CPAP titration is attempted.
- Strategy 4 (“HomeDx, SpNPSG(+)”). All people in the hypothetical cohort will be assessed in the home setting with portable sleep monitors (HomeDx). Those with positive diagnoses (indexed by the “+” sign in the name of the strategy) will be subjected to split-night studies in the sleep laboratory, to verify the diagnosis and to titrate CPAP level (if applicable). This is a combination of strategies 3 and 6 (see below).
- Strategy 5 (“HomeDx, SpNPSG(−)”). This is similar to Strategy 4 in structure, but here people with positive diagnoses in the home setting are offered CPAP level titration, and people with negative diagnoses in the home setting will be re-evaluated with split-night studies in the lab (to minimize the number of people with OSAHS who have been missed as false negatives).
- Strategy 6 (“HomeDx, autoCPAP”). The whole hypothetical cohort is managed entirely outside the sleep laboratory. Portable monitoring in the home setting (“HomeDx”) is used for the diagnosis, and auto-titration of CPAP is attempted again in the home setting on a different night.
- Strategy 7 (“All on CPAP”). The whole cohort will be offered CPAP treatment (with auto-titration or empirical titration of the pressure level). In this scenario none is tested for OSAHS. This is the other extreme scenario that has been included for comparison.

As stated, different simulations were run for middle-aged people and for older adults.

In the following paragraphs we summarize the results of the modeled strategies. We emphasize once more that these are the results of the baseline analyses; the corresponding sensitivity analyses are reported in the text.

Table A shows the proportion of people who are offered CPAP (who had “positive diagnoses”) in the hypothetical cohorts, in the baseline analyses. One could argue that we are mostly interested in maximizing the proportion of people who have OSAHS and are correctly offered CPAP as treatment (“true positives”). Letting aside strategy 7 that offers CPAP to all patients, irrespective of diagnosis, strategy 2 and strategy 5 maximize “true positives”.

As shown in Table A, strategy 5 is expected to yield a lot of “false positives” in both cohorts. Although there are no data supporting immediate and detrimental health events among people without OSAHS who are (erroneously) offered CPAP, “false positives” might be associated with psychological stress secondary to labeling or other non-desirable outcomes.

Table A Proportion of people who are offered CPAP (i.e,, proportion with a positive diagnosis) in the hypothetical cohorts

Strategy (for diagnosis and CPAP titration) | Proportion offered CPAP (%)
Strategy (for diagnosis and CPAP titration) | Middle-aged people (~50 years old) | | | Older adults (~70 years old)
Strategy (for diagnosis and CPAP titration) | All | With OSAHS^*^ | Without OSAHS^*^ | All | With OSAHS^*^ | Without OSAHS^*^
1. None started on CPAP | 0 | 0 | 0 | 0 | 0 | 0
2. Full night PSG, treatment PSG | 54 | 100 | 0 | 27 | 100 | 0
3. Split-night PSG | 51 | 89 | 6 | 28 | 89 | 6
4. Home diagnosis, split-night PSG to verify positive cases | 44 | 81 | 1 | 23 | 81 | 2
5. Home diagnosis, split-night PSG in all negative cases | 62 | 99 | 20 | 52 | 99 | 34
6. Home diagnosis, home CPAP titration | 56 | 91 | 15 | 46 | 91 | 30
7. All started on CPAP | 100 | 100 | 100 | 100 | 100 | 100

CPAP: continuous positive airway pressure; OSAHS: Obstructive sleep apnea-hypopnea syndrome (see methods for definition)

* OSAHS was operationally defined as the presence of symptoms and signs along with an apnea-hypopnea index more than 15 events/hour in facility-based PSG.

Table B summarizes the baseline analyses for the mean time to final diagnosis in the 2 cohorts. There was little good quality evidence in the published literature that informed on the average waiting time for a sleep study in the lab setting. This is a key quantity in the modeling, central to the numerical estimates for time to final diagnosis for strategies 2 to 5. Based on the best available evidence, we set the mean waiting time for a sleep study in the lab would be 13 weeks for strategy 2 (and the corresponding quantities for strategies 3, 4 and 5 were calculated to be 68, 36 and 27 percent of that value). The results section provides sensitivity analyses a range of assumed average waiting times in strategy 2.

The estimates among older adults are roughly similar to the estimates among younger people. The results sections’ sensitivity analyses help explain the small differences.

Conceptually, one would favor strategies that result in shorter time to diagnosis. Shorter time to diagnosis reflects more “efficient” strategies. Furthermore, one can hypothesize that shorter time to diagnosis may reduce patient anxiety, or encourage a modification of health habits and lifestyle. Generally, shorter time to diagnosis also implies shorter time to CPAP treatment initiation (see below).

Table B Mean time to (final) diagnosis of OSAHS with a sleep study in the hypothetical cohorts – baseline analyses

Strategy (for diagnosis and CPAP titration) | Mean time to diagnosis (Weeks)
Strategy (for diagnosis and CPAP titration) | Middle-aged people (~50 years) | Older adults (~70 years)
1. None started on CPAP | NA^a^ | NA^a^
2. Full night PSG, treatment PSG | 13.6 | 11.2
3. Split-night PSG | 9.8 | 9.8
4. Home diagnosis, split-night PSG to verify positive cases | 4.8 | 4.0
5. Home diagnosis, split-night PSG in all negative cases | 3.8 | 4.5
6. Home diagnosis, home CPAP titration | 2.1 | 2.1
7. All started on CPAP | NA^a^ | NA^a^

CPAP: continuous positive airway pressure; NA: not applicable; OSAHS: Obstructive sleep apnea-hypopnea syndrome (see methods for definition).

a No diagnostic assessment is performed in these strategies

The numbers for strategies 2 to 5 are very much dependent on the assumed average waiting time for a sleep study in the lab setting.

Table C summarizes the baseline analyses for the mean time to CPAP among people offered CPAP in the 2 cohorts. Again, the key quantity in the modeling is the average waiting time for a sleep study in the lab setting. The calculated times change proportionally, when different average waiting times are assumed, as shown in the results section, where detailed estimates for a range of assumed average waiting times are provided.

The calculated mean times among older adults are roughly similar to the estimates among younger people. The results sections’ sensitivity analyses help explain the small differences.

Table C Mean time to CPAP in the hypothetical cohorts

Strategy (for diagnosis and CPAP titration) | Mean time to CPAP^*^ (among those offered CPAP) [weeks]
Strategy (for diagnosis and CPAP titration) | Middle-aged people (~50 years) | Older adults (~70 years)
1. None started on CPAP | NA^a^ | NA^a^
2. Full night PSG, treatment PSG | 27.3 | 22.4
3. Split-night PSG | 9.8 | 9.8
4. Home diagnosis, split-night PSG to verify positive cases | 5.0 | 5.8
5. Home diagnosis, split-night PSG in all negative cases | 6.2 | 7.2
6. Home diagnosis, home CPAP titration | 4.8 | 4.5
7. All started on CPAP | NA^a^ | NA^a^

CPAP: continuous positive airway pressure; OSAHS: Obstructive sleep apnea-hypopnea syndrome (see methods for definition).

* “Time to CPAP” means time to a technically adequate CPAP titration study.

a Not meaningful to assess – none (strategy 1) or all (strategy 7) patients offered CPAP in these strategies

Shorter time to CPAP initiation for people who have the disease means that any benefits from CPAP therapy will not be unnecessarily delayed. However, there are no randomized data on the exact clinical importance of e.g. a 6-month delay in CPAP treatment with respect to clinical outcomes such as deaths, cardiovascular disease, stroke etc. One may postulate expected beneficial health outcomes: There is randomized evidence that CPAP versus no treatment or sham CPAP treatment of OSAHS is associated with improvements in quality of life outcomes or intermediate clinical outcomes (e.g., hypertension). Observational evidence from prospective comparative studies associates CPAP treatment of OSAHS with fewer cardiovascular events. Furthermore, patients with OSAHS have an increased risk for car accidents. CPAP has also been associated with a reduction in the risk for motor vehicle accidents among people with OSAHS.

The current modeling illustrates the tradeoff in the number of people with OSAHS who are offered CPAP and time to diagnosis or technically adequate CPAP level titration across seven different simulated strategies. Strategies that use portable monitors as a first (or only) test generally result in shorter average time to diagnosis and technically adequate CPAP level titration, but also in increased numbers of “false positives” or “false negatives” (depending on the strategy) compared to facility-based PSG. Diagnosis and CPAP level titration entirely in the sleep labs or related facilities may result in better diagnostic accuracy, but is likely to result in longer time to diagnosis and CPAP level titration. As discussed in the previous technology assessment (“Home diagnosis of Obstructive Sleep Apnea-Hypopnea Syndrome” by the Tufts-New England Medical Center Evidence-based Practice Center), more evidence is needed on both PSG and portable monitors to predict response to CPAP and changes in clinical outcomes after CPAP treatment.