# References

1 Practice parameters for the indications for polysomnography and related procedures. Polysomnography Task Force, American Sleep Disorders Association Standards of Practice Committee. Sleep. 1997;20(6):406-422. [pmid: 9302725].
2 Marin JM, Carrizo SJ, Vicente E, Agusti AG. Long-term cardiovascular outcomes in men with obstructive sleep apnoea-hypopnoea with or without treatment with continuous positive airway pressure: an observational study. Lancet. 2005;365(9464):1046-1053. [pmid: 15781100].
3 Yaggi HK, Concato J, Kernan WN, et al. Obstructive sleep apnea as a risk factor for stroke and death. N Engl J Med. 2005;353(19):2034-2041. [pmid: 16282178].
4 Buchner NJ, Sanner BM, Borgel J, Rump LC. CPAP Treatment of Mild to Moderate Obstructive Sleep Apnea Reduces Cardiovascular Risk. Am J Respir Crit Care Med. 2007.
5 Young T, Palta M, Dempsey J, et al. The occurrence of sleep-disordered breathing among middle-aged adults. N Engl J Med. 1993;328(17):1230-1235. [pmid: 8464434].
6 Shahar E, Whitney CW, Redline S, et al. Sleep-disordered breathing and cardiovascular disease: cross-sectional results of the Sleep Heart Health Study. Am J Respir Crit Care Med. 2001;163(1):19-25. [pmid: 11208620].
7 Nieto FJ, Young TB, Lind BK, et al. Association of sleep-disordered breathing, sleep apnea, and hypertension in a large community-based study. Sleep Heart Health Study. JAMA. 2000;283(14):1829-1836. [pmid: 10770144].
8 Peppard PE, Young T, Palta M, Skatrud J. Prospective study of the association between sleep-disordered breathing and hypertension. N Engl J Med. 2000;342(19):1378-1384. [pmid: 10805822].
9 Young T, Peppard P, Palta M, et al. Population-based study of sleep-disordered breathing as a risk factor for hypertension. Arch Intern Med. 1997;157(15):1746-1752. [pmid: 9250236].
10 Babu AR, Herdegen J, Fogelfeld L, Shott S, Mazzone T. Type 2 diabetes, glycemic control, and continuous positive airway pressure in obstructive sleep apnea. Arch Intern Med. 2005;165(4):447-452. [pmid: 15738376].
11 Gruber A, Horwood F, Sithole J, Ali NJ, Idris I. Obstructive sleep apnoea is independently associated with the metabolic syndrome but not insulin resistance state. Cardiovasc Diabetol. 2006;5:22. [pmid: 17078884].
12 Howard ME, Desai AV, Grunstein RR, et al. Sleepiness, sleep-disordered breathing, and accident risk factors in commercial vehicle drivers. Am J Respir Crit Care Med. 2004;170(9):1014-1021. [pmid: 15317672].
13 Teran-Santos J, Jimenez-Gomez A, Cordero-Guevara J. The association between sleep apnea and the risk of traffic accidents. Cooperative Group Burgos-Santander. N Engl J Med. 1999;340(11):847-851. [pmid: 10080847].
14 Flemons WW, Littner MR, Rowley JA, et al. Home diagnosis of sleep apnea: a systematic review of the literature. An evidence review cosponsored by the American Academy of Sleep Medicine, the American College of Chest Physicians, and the American Thoracic Society. Chest. 2003;124(4):1543-1579. [pmid: 14555592].
15 Kingshott RN, Engleman HM, Deary IJ, Douglas NJ. Does arousal frequency predict daytime function?. Eur Respir J. 1998;12(6):1264-1270. [pmid: 9877475].
16 Young T, Peppard PE, Taheri S. Excess weight and sleep-disordered breathing. J Appl Physiol. 2005;99(4):1592-1599. [pmid: 16160020].
17 Young T, Shahar E, Nieto FJ, et al. Predictors of sleep-disordered breathing in community-dwelling adults: the Sleep Heart Health Study. Arch Intern Med. 2002;162(8):893-900. [pmid: 11966340].
18 Ancoli-Israel S, Kripke DF, Klauber MR, et al. Sleep-disordered breathing in community-dwelling elderly. Sleep. 1991;14(6):486-495. [pmid: 1798880].
19 Bixler EO, Vgontzas AN, Ten HT, Tyson K, Kales A. Effects of age on sleep apnea in men: I. Prevalence and severity. Am J Respir Crit Care Med. 1998;157(1):144-148. [pmid: 9445292].
20 Bixler EO, Vgontzas AN, Lin HM, et al. Prevalence of sleep-disordered breathing in women: effects of gender. Am J Respir Crit Care Med. 2001;163(3 Pt 1):608-613. [pmid: 11254512].
21 Duran J, Esnaola S, Rubio R, Iztueta A. Obstructive sleep apnea-hypopnea and related clinical features in a population-based sample of subjects aged 30 to 70 yr. Am J Respir Crit Care Med. 2001;163(3 Pt 1):685-689. [pmid: 11254524].
22 Young T, Peppard PE, Gottlieb DJ. Epidemiology of obstructive sleep apnea: a population health perspective. Am J Respir Crit Care Med. 2002;165(9):1217-1239. [pmid: 11991871].
23 Ferber R, Millman R, Coppola M, et al. Portable recording in the assessment of obstructive sleep apnea. ASDA standards of practice. Sleep. 1994;17(4):378-392. [pmid: 7973323].
24 Patel SR, White DP, Malhotra A, Stanchina ML, Ayas NT. Continuous positive airway pressure therapy for treating sleepiness in a diverse population with obstructive sleep apnea: results of a meta-analysis. Arch Intern Med. 2003;163(5):565-571. [pmid: 12622603].
25 Engleman HM, sgari-Jirhandeh N, McLeod AL, et al. Self-reported use of CPAP and benefits of CPAP therapy: a patient survey. Chest. 1996;109(6):1470-1476. [pmid: 8769496].
26 George CF. Reduction in motor vehicle collisions following treatment of sleep apnoea with nasal CPAP. Thorax. 2001;56(7):508-512. [pmid: 11413347].
27 Krieger J, Meslier N, Lebrun T, et al. Accidents in obstructive sleep apnea patients treated with nasal continuous positive airway pressure: a prospective study. The Working Group ANTADIR, Paris and CRESGE, Lille, France. Association Nationale de Traitement a Domicile des Insuffisants Respiratoires. Chest. 1997;112(6):1561-1566. [pmid: 9404754].
28 Giles TL, Lasserson TJ, Smith BJ, et al. Continuous positive airways pressure for obstructive sleep apnoea in adults. Cochrane Database Syst Rev. 2006;(1):CD001106.
29 Flemons WW, Reimer MA. Development of a disease-specific health-related quality of life questionnaire for sleep apnea. Am J Respir Crit Care Med. 1998;158(2):494-503. [pmid: 9700127].
30 Lux L, Boehlecke B, Lohr KN. Effects of portable monitoring devices for diagnosing obstructive sleep apnea: Update of a systematic review. 290-20-0016. 2006. Agency for Healthcare Research and Quality.
31 Beck JR, Pauker SG. The Markov process in medical prognosis. Med Decis Making. 1983;3(4):419-458. [pmid: 6668990].
32 Chapman GB, Sonnenberg FA. Decision making in health care. Theory, psychology and applications. New York. Cambridge University Press. 2003.
33 Pettiti DB. Meta-analysis, decision analysis and cost-effectiveness analysis. New York. Oxford University Press. 1994.
34 Sokol J. An intuitive Markov chain lesson from baseball. http://ite.pubs.informs.org/Vol5No1/Sokol. 2007.
35 Alvarez D, Hornero R, Abasolo D, del CF, Zamarron C. Nonlinear characteristics of blood oxygen saturation from nocturnal oximetry for obstructive sleep apnoea detection. Physiological Measurement. 2006;27(4):399-412. [pmid: 16537981].
36 Ayappa I, Norman RG, Suryadevara M, Rapoport DM. Comparison of limited monitoring using a nasal-cannula flow signal to full polysomnography in sleep-disordered breathing. Sleep. 2004;27(6):1171-1179. [pmid: 15532212].
37 Baltzan MA, Verschelden P, Al-Jahdali H, Olha AE, Kimoff RJ. Accuracy of oximetry with thermistor (OxiFlow) for diagnosis of obstructive sleep apnea and hypopnea. Sleep. 2000;23(1):61-69. [pmid: 10678466].
38 Chiner E, Signes-Costa J, Arriero JM, et al. Nocturnal oximetry for the diagnosis of the sleep apnoea hypopnoea syndrome: a method to reduce the number of polysomnographies?[see comment]. Thorax. 1999;54(11):968-971. [pmid: 10525553].
39 Dingli K, Coleman EL, Vennelle M, et al. Evaluation of a portable device for diagnosing the sleep apnoea/hypopnoea syndrome. European Respiratory Journal. 2003;21(2):253-259. [pmid: 12608438].
40 Gugger M. Comparison of ResMed AutoSet (version 3.03) with polysomnography in the diagnosis of the sleep apnoea/hypopnoea syndrome. European Respiratory Journal. 1997;10(3):587-591. [pmid: 9072989].
41 Issa FG, Morrison D, Hadjuk E, et al. Digital monitoring of sleep-disordered breathing using snoring sound and arterial oxygen saturation. American Review of Respiratory Disease. 1993;148(4:Pt 1):t-9.
42 Levy P, Pepin JL, schaux-Blanc C, Paramelle B, Brambilla C. Accuracy of oximetry for detection of respiratory disturbances in sleep apnea syndrome. Chest. 1996;109(2):395-399. [pmid: 8620711].
43 Man GC, Kang BV. Validation of a portable sleep apnea monitoring device. Chest. 1995;108(2):388-393. [pmid: 7634872].
44 Mayer P, Meurice JC, Philip-Joet F, et al. Simultaneous laboratory-based comparison of ResMed Autoset with polysomnography in the diagnosis of sleep apnoea/hypopnoea syndrome. European Respiratory Journal. 1998;12(4):770-775. [pmid: 9817143].
45 Michaelson PG, Allan P, Chaney J, Mair EA. Validations of a portable home sleep study with twelve-lead polysomnography: comparisons and insights into a variable gold standard. Annals of Otology, Rhinology & Laryngology. 2006;115(11):802-809.
46 Mykytyn IJ, Sajkov D, Neill AM, McEvoy RD. Portable computerized polysomnography in attended and unattended settings. Chest. 1999;115(1):114-122. [pmid: 9925071].
47 Pang KP, Dillard TA, Blanchard AR, et al. A comparison of polysomnography and the SleepStrip in the diagnosis of OSA. Otolaryngology - Head & Neck Surgery. 2006;135(2):265-268. [pmid: 16890080].
48 Parra O, Garcia-Esclasans N, Montserrat JM, et al. Should patients with sleep apnoea/hypopnoea syndrome be diagnosed and managed on the basis of home sleep studies?[see comment]. European Respiratory Journal. 1997;10(8):1720-1724. [pmid: 9272909].
49 Penzel T, Kesper K, Pinnow I, Becker HF, Vogelmeier C. Peripheral arterial tonometry, oximetry and actigraphy for ambulatory recording of sleep apnea. Physiological Measurement. 2004;25(4):1025-1036. [pmid: 15382839].
50 Pittman SD, Ayas NT, MacDonald MM, et al. Using a wrist-worn device based on peripheral arterial tonometry to diagnose obstructive sleep apnea: in-laboratory and ambulatory validation. Sleep. 2004;27(5):923-933. [pmid: 15453551].
51 Pittman SD, MacDonald MM, Fogel RB, et al. Assessment of automated scoring of polysomnographic recordings in a population with suspected sleep-disordered breathing. Sleep. 2004;27(7):1394-1403. [pmid: 15586793].
52 Portier F, Portmann A, Czernichow P, et al. Evaluation of home versus laboratory polysomnography in the diagnosis of sleep apnea syndrome. American Journal of Respiratory & Critical Care Medicine. 2000;162(3:Pt 1):t-8.
53 Rauscher H, Popp W, Zwick H. Model for investigating snorers with suspected sleep apnoea. Thorax. 1993;48(3):275-279. [pmid: 8497828].
54 Rees K, Wraith PK, Berthon-Jones M, Douglas NJ. Detection of apnoeas, hypopnoeas and arousals by the AutoSet in the sleep apnoea/hypopnoea syndrome. European Respiratory Journal. 1998;12(4):764-769. [pmid: 9817142].
55 Reichert JA, Bloch DA, Cundiff E, Votteri BA. Comparison of the NovaSom QSG, a new sleep apnea home-diagnostic system, and polysomnography. Sleep Medicine. 2003;4(3):213-218. [pmid: 14592324].
56 Ryan PJ, Hilton MF, Boldy DA, et al. Validation of British Thoracic Society guidelines for the diagnosis of the sleep apnoea/hypopnoea syndrome: can polysomnography be avoided?. Thorax. 1995;50(9):972-975. [pmid: 8539678].
57 Su S, Baroody FM, Kohrman M, Suskind D. A comparison of polysomnography and a portable home sleep study in the diagnosis of obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery. 2004;131(6):844-850. [pmid: 15577778].
58 Van Surell C, Lemaigre D, Leroy M, et al. Evaluation of an ambulatory device, CID 102, in the diagnosis of obstructive sleep apnoea syndrome. European Respiratory Journal. 1995;8(5):795-800. [pmid: 7656952].
59 Verse T, Pirsig W, Junge-Hulsing B, Kroker B. Validation of the POLY-MESAM seven-channel ambulatory recording unit. Chest. 2000;117(6):1613-1618. [pmid: 10858392].
60 White DP, Gibb TJ, Wall JM, Westbrook PR. Assessment of accuracy and analysis time of a novel device to monitor sleep and breathing in the home.[see comment]. Sleep. 1995;18(2):115-126. [pmid: 7792491].
61 Zucconi M, Ferini-Strambi L, Castronovo V, Oldani A, Smirne S. An unattended device for sleep-related breathing disorders: validation study in suspected obstructive sleep apnoea syndrome. European Respiratory Journal. 1996;9(6):1251-1256. [pmid: 8804946].
62 Ancoli-Israel S, Mason W, Coy TV, et al. Evaluation of sleep disordered breathing with unattended recording: the Nightwatch System. Journal of Medical Engineering & Technology. 1997;21(1):10-14. [pmid: 9080356].
63 Bar A, Pillar G, Dvir I, et al. Evaluation of a portable device based on peripheral arterial tone for unattended home sleep studies.[see comment]. Chest. 2003;123(3):695-703. [pmid: 12628865].
64 Esnaola S, Duran J, Infante-Rivard C, Rubio R, Fernandez A. Diagnostic accuracy of a portable recording device (MESAM IV) in suspected obstructive sleep apnoea. European Respiratory Journal. 1996;9(12):2597-2605. [pmid: 8980975].
65 Fry JM, DiPhillipo MA, Curran K, Goldberg R, Baran AS. Full polysomnography in the home. Sleep. 1998;21(6):635-642. [pmid: 9779523].
66 Gagnadoux F, Pelletier-Fleury N, Philippe C, Rakotonanahary D, Fleury B. Home unattended vs hospital telemonitored polysomnography in suspected obstructive sleep apnea syndrome: a randomized crossover trial. Chest. 2002;121(3):753-758. [pmid: 11888956].
67 Hedner J, Pillar G, Pittman SD, et al. A novel adaptive wrist actigraphy algorithm for sleep-wake assessment in sleep apnea patients. Sleep. 2004;27(8):1560-1566. [pmid: 15683148].
68 Ip MS, Lam B, Tang LC, et al. A community study of sleep-disordered breathing in middle-aged Chinese women in Hong Kong: prevalence and gender differences. Chest. 2004;125(1):127-134. [pmid: 14718431].
69 Kapur VK, Rapoport DM, Sanders MH, et al. Rates of sensor loss in unattended home polysomnography: the influence of age, gender, obesity, and sleep-disordered breathing. Sleep. 2000;23(5):682-688. [pmid: 10947036].
70 Margel D, Cohen M, Livne PM, Pillar G. Severe, but not mild, obstructive sleep apnea syndrome is associated with erectile dysfunction. Urology. 2004;63(3):545-549. [pmid: 15028455].
71 Masa JF, Corral J, Martin MJ, et al. Assessment of thoracoabdominal bands to detect respiratory effort-related arousal. European Respiratory Journal. 2003;22(4):661-667. [pmid: 14582921].
72 Neven AK, Middelkoop HA, Kemp B, Kamphuisen HA, Springer MP. The prevalence of clinically significant sleep apnoea syndrome in The Netherlands. Thorax. 1998;53(8):638-642. [pmid: 9828848].
73 Series F, Marc I, Cormier Y, La FJ. Utility of nocturnal home oximetry for case finding in patients with suspected sleep apnea hypopnea syndrome.[see comment]. Annals of Internal Medicine. 1993;119(6):449-453. [pmid: 8357109].
74 Series F, Marc I. Nasal pressure recording in the diagnosis of sleep apnoea hypopnoea syndrome.[see comment]. Thorax. 1999;54(6):506-510. [pmid: 10335004].
75 Vazquez JC, Tsai WH, Flemons WW, et al. Automated analysis of digital oximetry in the diagnosis of obstructive sleep apnoea. Thorax. 2000;55(4):302-307. [pmid: 10722770].
76 Zamarron C, Romero PV, Rodriguez JR, Gude F. Oximetry spectral analysis in the diagnosis of obstructive sleep apnoea. Clinical Science. 1999;97(4):467-473. [pmid: 10491347].
77 Zamarron C, Gude F, Barcala J, Rodriguez JR, Romero PV. Utility of oxygen saturation and heart rate spectral analysis obtained from pulse oximetric recordings in the diagnosis of sleep apnea syndrome. Chest. 2003;123(5):1567-1576. [pmid: 12740275].
78 Zou D, Grote L, Peker Y, Lindblad U, Hedner J. Validation a portable monitoring device for sleep apnea diagnosis in a population based cohort using synchronized home polysomnography. Sleep. 2006;29(3):367-374. [pmid: 16553023].
79 Chung KF. Half-night polysomnography: how is it compared to full-night polysomnography?. Eur Respir J. 1998;12(3):748-749. [pmid: 9762809].
80 Fanfulla F, Patruno V, Bruschi C, Rampulla C. Obstructive sleep apnoea syndrome: is the"half-night polysomnography" an adequate method for evaluating sleep profile and respiratory events?. Eur Respir J. 1997;10(8):1725-1729. [pmid: 9272910].
81 Sanders MH, Black J, Costantino JP, et al. Diagnosis of sleep-disordered breathing by half-night polysomnography. Am Rev Respir Dis. 1991;144(6):1256-1261. [pmid: 1741536].
82 Calleja JM, Esnaola S, Rubio R, Duran J. Comparison of a cardiorespiratory device versus polysomnography for diagnosis of sleep apnoea. European Respiratory Journal. 2002;20(6):1505-1510. [pmid: 12503711].
83 Claman D, Murr A, Trotter K. Clinical validation of the Bedbugg in detection of obstructive sleep apnea. Otolaryngol Head Neck Surg. 2001;125(3):227-230. [pmid: 11555758].
84 Fietze I, Glos M, Rottig J, Witt C. Automated analysis of data is inferior to visual analysis of ambulatory sleep apnea monitoring. Respiration. 2002;69(3):235-241. [pmid: 12097767].
85 Ayas NT, Pittman S, MacDonald M, White DP. Assessment of a wrist-worn device in the detection of obstructive sleep apnea. Sleep Medicine. 2003;4(5):435-442. [pmid: 14592285].
86 Schafer H, Ewig S, Hasper E, Luderitz B. Predictive diagnostic value of clinical assessment and nonlaboratory monitoring system recordings in patients with symptoms suggestive of obstructive sleep apnea syndrome. Respiration. 1997;64(3):194-199. [pmid: 9154670].
87 Bearpark H, Elliott L, Grunstein R, et al. Snoring and sleep apnea. A population study in Australian men. American Journal of Respiratory & Critical Care Medicine. 1995;151(5):1459-1465. [pmid: 7735600].
88 Bednarek M, Plywaczewski R, Jonczak L, Zielinski J. There is no relationship between chronic obstructive pulmonary disease and obstructive sleep apnea syndrome: a population study. Respiration. 2005;72(2):142-149. [pmid: 15824523].
89 Golpe R, Jimenez A, Carpizo R. Home sleep studies in the assessment of sleep apnea/hypopnea syndrome. Chest. 2002;122(4):1156-1161. [pmid: 12377836].
90 Middelkoop HA, Knuistingh NA, van Hilten JJ, Ruwhof CW, Kamphuisen HA. Wrist actigraphic assessment of sleep in 116 community based subjects suspected of obstructive sleep apnoea syndrome. Thorax. 1995;50(3):284-289. [pmid: 7660344].
91 Quintana-Gallego E, Villa-Gil M, Carmona-Bernal C, et al. Home respiratory polygraphy for diagnosis of sleep-disordered breathing in heart failure. European Respiratory Journal. 2004;24(3):443-448. [pmid: 15358704].
92 Westbrook PR, Levendowski DJ, Cvetinovic M, et al. Description and validation of the apnea risk evaluation system: a novel method to diagnose sleep apnea-hypopnea in the home. Chest. 2005;128(4):2166-2175. [pmid: 16236870].
93 Whittle AT, Finch SP, Mortimore IL, Mackay TW, Douglas NJ. Use of home sleep studies for diagnosis of the sleep apnoea/hypopnoea syndrome. Thorax. 1997;52(12):1068-1073. [pmid: 9516901].
94 Williams AJ, Yu G, Santiago S, Stein M. Screening for sleep apnea using pulse oximetry and a clinical score. Chest. 1991;100(3):631-635. [pmid: 1889245].
95 Fletcher EC, Stich J, Yang KL. Unattended home diagnosis and treatment of obstructive sleep apnea without polysomnography. Arch Fam Med. 2000;9(2):168-174. [pmid: 10693735].
96 Flemons WW, Douglas NJ, Kuna ST, Rodenstein DO, Wheatley J. Access to diagnosis and treatment of patients with suspected sleep apnea. Am J Respir Crit Care Med. 2004;169(6):668-672. [pmid: 15003950].
97 Pittsley M, Gehrman P, Cohen-Zion M, et al. Comparing night-to-night variability of sleep measures in elderly African Americans and Whites. Behav Sleep Med. 2005;3(2):63-72. [pmid: 15802257].
98 Li AM, Wing YK, Cheung A, et al. Is a 2-night polysomnographic study necessary in childhood sleep-related disordered breathing?. Chest. 2004;126(5):1467-1472. [pmid: 15539714].
99 Chu H, Cole SR. Bivariate meta-analysis of sensitivity and specificity with sparse data: a generalized linear mixed model approach. J Clin Epidemiol. 2006;59(12):1331-1332. [pmid: 17098577].
100 Harbord RM, Deeks JJ, Egger M, Whiting P, Sterne JA. A unification of models for meta-analysis of diagnostic accuracy studies. Biostatistics. 2007;8(2):239-251. [pmid: 16698768].
101 Rutter CM, Gatsonis CA. A hierarchical regression approach to meta-analysis of diagnostic test accuracy evaluations. Stat Med. 2001;20(19):2865-2884. [pmid: 11568945].
102 Lloberes P, Montserrat JM, Ascaso A, et al. Comparison of partially attended night time respiratory recordings and full polysomnography in patients with suspected sleep apnoea/hypopnoea syndrome. Thorax. 1996;51(10):1043-1047. [pmid: 8977607].
103 Orr WC, Eiken T, Pegram V, Jones R, Rundell OH. A laboratory validation study of a portable system for remote recording of sleep-related respiratory disorders. Chest. 1994;105(1):160-162. [pmid: 8275725].
104 Stoohs R, Guilleminault C. MESAM 4: an ambulatory device for the detection of patients at risk for obstructive sleep apnea syndrome (OSAS). Chest. 1992;101(5):1221-1227. [pmid: 1582275].
105 Hutter DA, Holland BK, Ashtyani H. Occult sleep apnea: the dilemma of negative polysomnography in symptomatic patients. Sleep Med. 2004;5(5):501-506. [pmid: 15341897].
106 Le Bon O, Hoffmann G, Tecco J, et al. Mild to moderate sleep respiratory events: one negative night may not be enough. Chest. 2000;118(2):353-359. [pmid: 10936124].
107 Quan SF, Griswold ME, Iber C, et al. Short-term variablility of respiration and sleep during unattended nonlaboratory polysomnogaphy--the Sleep Heart Health Study. Sleep. 2002;25(8):843-849. [pmid: 12489889].
108 Mulgrew AT, Fox N, Ayas NT, Ryan CF. Diagnosis and initial management of obstructive sleep apnea without polysomnography: a randomized validation study. Annals of Internal Medicine. 2007;146(3):157-166. [pmid: 17283346].
109 Shariq K. Sleep centers in the U.S. reach 2515 in 2004. Sleep. 2005;28(1):145-146. [pmid: 15700729].
110 Johns MW. A new method for measuring daytime sleepiness: the Epworth sleepiness scale. Sleep. 1991;14(6):540-545. [pmid: 1798888].
111 Wells GA, Tugwell P, Kraag GR, et al. Minimum important difference between patients with rheumatoid arthritis: the patient's perspective. J Rheumatol. 1993;20(3):557-560. [pmid: 8478873].
112 Kosinski M, Zhao SZ, Dedhiya S, Osterhaus JT, Ware JE Jr. Determining minimally important changes in generic and disease-specific health-related quality of life questionnaires in clinical trials of rheumatoid arthritis. Arthritis Rheum. 2000;43(7):1478-1487. [pmid: 10902749].
113 Mehra R, Strohl KP. Incidence of serious adverse events during nocturnal polysomnography.[see comment]. Sleep. 2004;27(7):1379-1383. [pmid: 15586791].
114 Bonis PA, Trikalinos TA, Chung M, et al. Hereditary nonpolyposis colorectal cancer: diagnostic strategies and their implications. Evid Rep Technol Assess (Full Rep). 2007;(150):1-180. [pmid: 17764220].
115 Pelletier-Fleury N, Meslier N, Gagnadoux F, et al. Economic arguments for the immediate management of moderate-to-severe obstructive sleep apnoea syndrome. Eur Respir J. 2004;23(1):53-60. [pmid: 14738231].
116 Mulherin SA, Miller WC. Spectrum bias or spectrum effect? Subgroup variation in diagnostic test evaluation. Ann Intern Med. 2002;137(7):598-602. [pmid: 12353947].
117 Bennett LS, Langford BA, Stradling JR, Davies RJ. Sleep fragmentation indices as predictors of daytime sleepiness and nCPAP response in obstructive sleep apnea. Am J Respir Crit Care Med. 1998;158(3):778-786. [pmid: 9731004].
118 d'Ortho MP, Grillier-Lanoir V, Levy P, et al. Constant vs. automatic continuous positive airway pressure therapy: home evaluation. Chest. 2000;118(4):1010-1017. [pmid: 11035671].
119 Hermida RC, Zamarron C, Ayala DE, Calvo C. Effect of continuous positive airway pressure on ambulatory blood pressure in patients with obstructive sleep apnoea. Blood Pressure Monitoring. 2004;9(4):193-202. [pmid: 15311146].
120 Lloberes P, Marti S, Sampol G, et al. Predictive factors of quality-of-life improvement and continuous positive airway pressure use in patients with sleep apnea-hypopnea syndrome: study at 1 year. Chest. 2004;126(4):1241-1247. [pmid: 15486388].
121 Marrone O, Salvaggio A, Bonsignore MR, Insalaco G, Bonsignore G. Blood pressure responsiveness to obstructive events during sleep after chronic CPAP. European Respiratory Journal. 2003;21(3):509-514. [pmid: 12662010].
122 Noseda A, Kempenaers C, Kerkhofs M, Houben JJ, Linkowski P. Sleep apnea after 1 year domiciliary nasal-continuous positive airway pressure and attempted weight reduction. Potential for weaning from continuous positive airway pressure. Chest. 1996;109(1):138-143. [pmid: 8549176].
123 Noseda A, Jann E, Hoffmann G, Linkowski P, Kerkhofs M. Compliance with nasal continuous positive airway pressure assessed with a pressure monitor: pattern of use and influence of sleep habits. Respiratory Medicine. 2000;94(1):76-81. [pmid: 10714483].
124 Whitelaw WA, Brant RF, Flemons WW. Clinical usefulness of home oximetry compared with polysomnography for assessment of sleep apnea.[see comment]. American Journal of Respiratory & Critical Care Medicine. 2005;171(2):188-193. [pmid: 15486338].
125 Flemons WW, Reimer MA. Measurement properties of the calgary sleep apnea quality of life index. Am J Respir Crit Care Med. 2002;165(2):159-164. [pmid: 11790647].