# Results

The search strategy yielded 299 articles. The selection process is described below:

The 114 included studies are comprised of 83 full reports, 30 abstract-only publications, and 1 citation in the grey literature (press releases, etc.). Study designs included 8 phase III controlled clinical trials, 14 phase II uncontrolled clinical trials, and 92 studies of other designs. The majority of the studies of other designs were retrospective series of patients receiving gefitinib under AstraZeneca’s pre-approval Expanded Access Program (EAP); these provided data on adverse events and predictors, but were not included in the assessment of efficacy.

## Efficacy

### First-line treatment combined with standard chemotherapy

There are four completed, large, randomized controlled phase III studies that compare EGFR-TK inhibitors in combination with standard chemotherapy against standard chemotherapy alone for patients with previously untreated advanced NSCLC (Table 2).6–9 Two of these used gefitinib6,7 and two, which have only been presented in abstract form, used erlotinib.8,9 The patient population and design of the studies were nearly identical except the studies with gefitinib used two different doses, 250 mg and 500 mg daily, in a three-arm study, while the erlotinib studies used a single dose. The chemotherapy used in the paired studies with each drug was standard combination chemotherapy of either carboplatin and paclitaxel in the North American study,6,8 or cisplatin and gemcitabine in the study done outside North America.7,9 None of the four studies showed a statistically significant difference in overall response rate (CR + PR) (Table 3), time to treatment failure (or progression-free survival), or overall survival (Table 4) between the EGFR-TK arm(s) and the placebo arm. Unpublished subgroup analysis of one study8 by smoking status showed an increase of median survival from 10 months in the placebo group to 22 months in the erlotinib-containing combination arm among the 8 percent of patients in the study who had never smoked. We are not aware of results of a similar analysis in the other three studies.

Table 2 First-line treatment with EGFR-TK inhibitors combined with cytotoxic agents for patients with advanced NSCLC

Study ID | EGFR-TK inhibitor dose [length of follow up] | Chemotherapy | No. of patients, age (median [range]), sex^*^ | Histology | Stage | PS | Smoking status | Outcomes sought
Phase III
Herbst et al., 2004^6^ | Gefitinib 250–500 mg/day [12 months] | Carboplatin AUC 6 mg/ml-min & paclitaxel 225 mg/m^2^×6 cycles | 1037 pts 62 (26–86) 40% F | Squamous 19.4% Adeno 51.9% Adenosquamous 1.7% BAC 3.2% NSCLC NOS 11.3% Large cell 11.0 | IIIA 3.8% IIIB 17.1% IIIB no pl eff 5.2% IIIB pl eff 11.9% IV 78.3% | 0: 38.8% 1: 51.9% 2: 9.3% | NR | 1. Overall survival 2. TTP Others: response rate, disease-related symptoms and QoL, toxicity
Giaccone et al., 2004^7^ | Gefitinib 250–500 mg/day [16 months] | Cisplatin 80 mg/m^2^ & gemcitabine 1250 mg/m^2^ ×6 cycles | 1093 pts 60 (31–85) 26% F | Squamous 29.2% Adeno 46.6% Adenosquamous 1.4% BAC 0.3% NSCLC NOS 11.8% Large cell 8.8% | IIIA 1.9% IIIB 28.4% IIIB no pl eff 6.6% IIIB pl eff 21.8% IV 68.6% | 0: 33.9% 1: 55.6% 2: 9.6% | NR | 1. Survival 2. TTP, response, toxicity
Miller et al., 2004^8^ | Erlotinib 150 mg/day [22 months] | Carboplatin/paclitaxel (6 cycles) | 1059 pts 62.6 (24–84) 38% F | Squamous 16% Adeno 61% Large cell 10% NSCLC NOS 12% | IV 82% | 0: 36.2% 1: 63.6% 2: 0.2% | Never: 8% | 1. Overall survival; Others: TTP, response rate, duration of response
Gatzemeier et al., 2004^9^ | Erlotinib 150 mg/day [NR] | Cisplatin 80 mg/m^2^ and gemcitabine 1250 mg/m^2^ ×6 cycles | ~1150 NR NR | NR | NR | 0/1: 100% | NR | 1. Survival Others: TTP, toxicity
Phase II
Williams et al., 2004^10^ | Gefitinib 250 mg/day [NR] | Docetaxel 75 mg/m^2^ every 3 weeks | 12 pts 74 (70–82) 25% F | NR | NR | NR | NR | Response, survival

* Patient characteristics based on placebo group when not reported for all patients in randomized controlled trial.

Abbreviations: Adeno = adenocarcinoma; AUC = area under the curve; BAC = bronchoalveolar carcinoma; EGFR-TK = epidermal growth factor receptor tyrosine kinase; F = female; No. = number; NR = not reported; NSCLC NOS = non-small cell lung cancer not otherwise specified; pl eff = pleural effusion; PS = performance status; pts = patients; TTP = time to progression

Table 3 Summary of tumor response in studies of first-line treatment with EGFR-TK inhibitors combined with cytotoxic agents for patients with advanced NSCLC

Study ID | Diagnosis (no. of patients) | Chemotherapy (all patients) | Sub-groups | Tumor response
Study ID | Diagnosis (no. of patients) | Chemotherapy (all patients) | Sub-groups | % CR | % PR | % SD | % DP | % NE
Phase III
Herbst et al., 2004^6^ | NSCLC (345) (345) (347) | Carboplatin AUC 6 mg/ml×min and paclitaxel 225 mg/m^2^ ×6 cycles | Placebo Gefitinib 250 mg/day Gefitinib 500 mg/day | 1.2 2.6 0.6 | 28.7 30.4 30.0 | - - - | - - - | - - -
Giaccone et al., 2004^7^ | NSCLC (363) (365) (365) | Cisplatin 80 mg/m^2^ and gemcitabine 1250 mg/m^2^ ×6 cycles | Placebo Gefitinib 250 mg/day Gefitinib 500 mg/day | 0.9 3.3 2.1 | 46.3 47.9 48.2 | - - - | - - - | - - -
Miller et al., 2004^8^ | NSCLC (533) (526) | Carboplatin/paclitaxel (6 cycles) | Placebo Erlotinib 150 mg/day | No differences between groups | - - | - - | - - | - -
Gatzemeier et al., 2004^9^ | NSCLC (~575) (~575) | Cisplatin 80 mg/m^2^ and gemcitabine 1250 mg/m^2^ ×6 cycles | Placebo Erlotinib 150 mg/day | NR | NR | NR | NR | NR
Phase II
Williams et al., 2004^10^ | NSCLC (12) | Docetaxel 75 mg/m^2^ every 3 weeks | Gefitinib 250 mg/day | 0 | 50 | 30 | 20 | -

Abbreviations: CR = complete response; DP = disease progression; EGFR-TK = epidermal growth factor receptor tyrosine kinase; NE = not evaluable; NSCLC = non-small cell lung cancer; no. = number; PR = partial response; SD = stable disease

Table 4 Summary of patient survival in studies of first-line treatment with EGFR-TK inhibitors combined with cytotoxic agents for advanced NSCLC

Study ID | Diagnosis (no. of patients) | Sub-groups (dosage in mg/day) | Survival from start of treatment | | | Progression-free survival
Study ID | Diagnosis (no. of patients) | Sub-groups (dosage in mg/day)
Study ID | Diagnosis (no. of patients) | Sub-groups (dosage in mg/day) | Median (months) | 1-year (%) | HR (95% CI) [p-value] | Median TTP (months) | 1-year (%) | HR (95% CI) [p-value]
Herbst et al., 2004^6^ | NSCLC (345) (345) (347) | Placebo Gefitinib 250 Gefitinib 500 | 9.9 9.8 8.7 | 42 41 37 | NS | 5.0 5.3 4.6 | - - - | NS
Giaccone et al., 2004^7^ | NSCLC (363) (365) (365) | Placebo Gefitinib 250 Gefitinib 500 | 10.0 9.9 9.9 | 44 41 43 | NS | 6.0 5.8 5.5 | - - - | NS
Miller et al., 2004^8^ | NSCLC (533) (526) | Placebo Erlotinib 150 | 10.5 10.6 | - - | 0.995 [p = 0.95; NS] | 4.9 5.1 | - - | 0.937 [p = 0.36, NS]
Gatzemeier et al., 2004^9^ | NSCLC (~575) (~575) | Placebo Erlotinib 150 | 10.2 9.9 | - - | NS | 5.9 5.5 | - - | NS

Abbreviations: CI = confidence interval; EGFR-TK = epidermal growth factor receptor tyrosine kinase; HR = hazard ratio; no. = number; NS = not statistically significant; NSCLC = non-small cell lung cancer; TTP = time to progression

In addition to the phase III studies, a single, small, uncontrolled phase II study of docetaxel 75 mg/m^2^ plus gefitinib 250 mg daily in patients at least 70 years of age reported a response rate of 50 percent.10

### First-line treatment as single agent

Eleven uncontrolled studies of gefitinib or erlotinib as a single agent in previously untreated patients with advanced NSCLC were identified (Table 5), seven of which11–17 were in unselected patients. Two of the studies were restricted to patients with bronchoalveolar carcinoma (BAC) histology,18,19 one included only patients age 70 and greater,20,21 and the remaining study required patients to have poor performance status (PS 2–3).22 The trials in unselected patients included a total of 293 patients and reported response rates ranging from 5 percent to 61 percent but with most falling between 25 percent and 33 percent (Table 6). The two studies in patients with BAC histology included patients who had been previously treated, but only one of these studies18 has yet reported the results separately for these two groups. The overall response rate in the two studies of BAC with gefitinib 500 mg daily and erlotinib 150 mg daily was 18 percent and 24 percent, respectively. In the study of gefitinib 500 mg daily, patients without prior treatment had a response rate of 21 percent compared to 10 percent in previously treated patients; however, the overall survival of the two groups was similar. In the study restricted to previously untreated elderly patients with advanced NSCLC, a response rate of 12 percent was reported.21 Finally, in a single study (18 evaluable patients) of patients with poor performance status, no responses were observed.22

Table 5 First-line treatment with EGFR-TK Inhibitors (single agent) for advanced NSCLC

Study ID | No. of patients, age (median [range]), sex | Histology | Stage | PS | Smoking status | EGFR-TK inhibitor dose/day | Outcomes sought
All NSCLC
Niho et al., 2004^11^ Phase II | 37 pts 61 (44–74) 35% F | Adeno n = 27 Squamous n = 3 Large cell n = 7 | IIIB: n = 3 IV: n = 34 | 0: n = 14 1: n = 23 | NR | Gefitinib 250 mg | Response Toxicity
Giaccone et al., 2005^12^ Phase II | 53 pts 61 (NR) 62%F | Adeno n = 23 Squamous n = 9 BAC n = 6 Large cell n = 8 Other n = 7 | NR | NR | Current: n = 10 Former: n = 25 Never: n = 18 | Erlotinib 150 mg | Response Survival TTP Safety
Kasahara et al., 2005^13^ Phase II | 30 pts 64 (44–87) 40%F | Adeno n=25 Squamous n-3 Large cell n=2 | IIIb n=4 IV n=26 | 0: n=20 1: n= 6 2: n= 4 | Yes n=20 No n=10 | Gefitinib 250 mg | Response Survival TTP Safety
Suzuki et al., 2005^14^ Phase II | 34 pts 64 (43–73) 38%F | Adeno n=25 Squamous n=5 Other n=4 | IV all | 0: n=16 1: n=18 | NR | Gefitinib 250 mg | Response QoL Toxicity
Reck et al., 2005^15^ Phase II | 58 pts 67 (41–84) NR | Adeno n=32 BAC n=10 Squamous n=8 Large cell n=4 Other n=4 | NR | 0: 10% 1: 66% 2: 24% | Current: 33% Former: 48% Never: 19% | Gefitinib 250 mg | Response PFS Toxicity
D’Addario et al., 2005^16^ Phase II | 63 pts 62 (39–85) 38%F | Adeno n=31 BAC n=6 Squamous n=17 Large cell n=6 Other n=3 | IIIb n=15 IV n=47 | 0: 57% 1: 43% | Never: n=9 | Gefitinib 250 mg | Response Survival
Lee et al., 2005^17^ Phase II | 55 pts 55 (40–74) 93%F | Adeno n=44 Adeno w/BAC n=11 | IIIb n=5 IV n=50 | 0: n=19 1: n=32 2: n= 3 | Never: 100% | Gefitinib 250 mg | Response
BAC
West et al., 2004^18^ Phase II | 138 pts^*^ 68 (34–89) 51% F | BAC 100% | NR | PS 0/1: 86% | NR | Gefitinib 500 mg | Response Survival Predictors
Kris et al., 2004^19^ Phase II | 69 pts^*^ 65 (33–85) 64% F | Pure BAC 25% Adeno/BAC 74% | NR | KPS ≥ 80: 91% | Never: 29% | Erlotinib 150 mg | Response Survival
Elderly
Jackman et al., 2005^21^ Phase II | 58 pts 75 (70–91) 47%F | Adeno 39 Adeno/BAC 9 Squamous 7 Large cell 2 NSCLC NOS 19 | NR | 0: 17% 1: 72% 2: 11% | Current: n = 3 Former: n = 49 Never: n = 6 | Erlotinib 150 mg | Survival Response
Poor PS
Dickson et al., 2004^22^ Phase II | 25 pts 64 (58–84) 32% F | BAC n = 2 Adeno n = 8 Squamous n = 8 Large cell n = 6 Other n = 1 | IIIB: 28% IV: 72% | 2: 80% 3: 20% | NR | Gefitinib 250 mg | Feasibility/toxicity Response rate Symptom response

* 26% of patients in both studies had previous chemotherapy

Abbreviations: Adeno = adenocarcinoma; Adeno/BAC = adenocarcinoma with bronchoalveolar carcinoma features; BAC = bronchoalveolar carcinoma; EGFR-TK = epidermal growth factor receptor tyrosine kinase; F = female; LCSS = Lung Cancer Symptom Scale; No. = number; NSCLC = non-small cell lung cancer; NSCLC NOS = non-small cell lung cancer not otherwise specified; PS = performance status; pts = patients; QoL = quality of life

Table 6 Summary of tumor response in studies of first-line treatment with EGFR-TK inhibitors (single agent) for advanced NSCLC

Study ID | Diagnosis (no. of patients) [agent] | Sub-groups | N | Survival from start of treatment | | Tumor response
Study ID | Diagnosis (no. of patients) [agent] | Sub-groups | N
Study ID | Diagnosis (no. of patients) [agent] | Sub-groups | N | Median (months) | 1-year (%) | % CR | % PR | % SD | % DP | % NE
All NSCLC
Niho et al., 2004^11^ | NSCLC (37) [Gefitinib] | - | 37 | - | - | 0 | 27 | - | - | -
Giaccone et al., 2005^12^ | NSCLC (53) [Erlotinib] | - | 53 | - | - | 2 | 23 | 30 | 32 | 13
Kasahara et al., 2005^13^ | NSCLC (30) [Gefitinib] | - | 30 | 10 | 43.3 | 0 | 33 | 30 | 37 | -
Suzuki et al., 2005^14^ | NSCLC (34) [Gefitinib] | - | 34 | - | - | 0 | 26 | - | - | -
Reck et al., 2005^15^ | NSCLC (58) [Gefitinib] | - | 58 | - | - | 2 | 3 | 40 | 48 | -
D’Addario et al., 2005^16^ | NSCLC (63) [Gefitinib] | - | 63 | 10 | - | 2 | 8 | 27 | 57 | 6
Lee et al., 2005^17^ | NSCLC (55) [Gefitinib] | - | 55 | Not reached | 76.1 | 4 | 57 | 11 | 28 | -
BAC
West et al., 2004^18^ | NSCLC (138) [Gefitinib] | Chemo-naïve Previous treatment (26%) | 67 21 | 12 10 | ~50 ~50 | 6 0 | 15 10 | - - | - - | - -
Kris et al., 2004^19^ | NSCLC (69) [Erlotinib] | - | 59 | Median not reached | 58 | - | 25 (15–38) | - | - | -
Elderly
Jackman et al., 2005^21^ | NSCLC (58) [erlotinib] | - | 66 | 11 | - | 0 | 12 | 48 | 39 | -
Poor PS
Dickson et al., 2004^22^ | NSCLC (25) [Gefitinib] | - | 18 | Median not reached | Follow up < 1 year | - | - | 61 | 39 | -

Abbreviations: BAC = bronchoalveolar carcinoma; CR = complete response; DP = disease progression; EGFR-TK = epidermal growth factor receptor tyrosine kinase; NE = not evaluable; NSCLC = non-small cell lung cancer; no. = number; PR = partial response; SD = stable disease

Survival data among all groups of studies show median survival of 10 to 12 months; some studies reported 1-year survival which ranged from 43 to 76 percent. Notably, compiled data from the EAP showed a median survival of 6 months and 1-year survival rate of 29.7 percent.23

### Second- or third-line treatment

Two randomized, placebo-controlled trials of single agent EGFR-TK inhibitors in previously treated patients have been completed and reported in preliminary form (Table 7). Both studies provided best supportive care to patients on both arms. In the BR21 trial, patients received either erlotinib 150 mg daily or placebo.24,25 As expected based on the earlier phase II study of erlotinib, the response rate (complete response plus partial response) was 9 percent versus < 1 percent in the placebo arm (Table 8). The median survival of 6.7 months in the erlotinib arm was 2 months longer than the placebo arm (Table 9). Progression-free survival and overall survival also significantly favored the erlotinib arm, with hazard ratios of 0.61 and 0.70, respectively. Multiple subgroup analyses indicated a survival advantage in every group examined except smoking status and possibly EGFR expression. The survival benefit among non-smokers (21 percent of subjects) was significantly greater than among the current or former smoker subgroup. Although survival was better among the smoker subgroup in the erlotinib arm, this advantage did not reach statistical significance. The availability of appropriate tumor tissue from only one-third of study subjects limited the analysis of EGFR expression correlation with survival, which suggested the possibility of a greater survival benefit in the EGFR-positive group. In contrast, a larger study of gefitinib in previously treated patients, which has been reported only as a press release from the pharmaceutical sponsor,26 failed to demonstrate a statistically significant advantage for the gefitinib-treated group (hazard ratio = 0.89, p = 0.11). Subgroup analysis suggested survival advantage in never smokers and East Asian patients, but not among those with adenocarcinoma. No quantitative estimates are available in the limited reporting in the press release; further analyses and more detailed reporting are expected.

Table 7 Second-line treatment with EGFR-TK inhibitors for advanced NSCLC

Study ID | No. of patients, age (median [range]), sex | Previous treatments | Histology | Stage | PS | Smoking status | EGFR-TK inhibitor dose/day | Outcomes sought
Phase III
Shepherd et al., 2005^25^ | 731 pts 62 (32–89) 35% F | 1 prior chemo: 50% 2 prior chemo: 49% chemo incl plat 92% | Adeno 50% Other 50% | NR | 0–1: 65% 2–3: 35% | Never 21% Current or former 73% Unk 5% | Erlotinib 150 mg | Survival, PFS, QoL, response, response duration, toxicity
ISEL press release, 2004^26^ | 1692 pts NR NR | NR | NR | NR | NR | NR | Gefitinib 250 mg | Survival
Phase II
Kris et al., 2003^29^ | 216 pts 61 (30–84) 46% F | 2 prior chemo: 40% 3 prior chemo: 30% ≥ 4 prior chemo: 28% | Adeno 69% Squamous 30% | IIIB: 15% IV: 85% | NR | NR | Gefitinib 250 mg vs. 500 mg | Response: bidimensional; Symptoms: FACT-L; Adverse events: NCI CTC 2.0
Fukuoka et al., 2003^30^ | 209 pts 61 (28–85) 29% F | Surgery: 31% XRT: 50% 1 prior chemo: 56% 2 prior chemo: 44% Immuno/hormonal treatment: 4% | Adeno 64% Squamous 24% Large cell 9% Undiff 3% | IIIA: 4% IIIB: 18% IV: 78% | NR | NR | Gefitinib 250 mg (500 mg on day 1) | Response: WHO criteria; Toxicity: NCI CTC; QoL: LCS
Perez-Soler et al., 2004^31^ | 57 pts 62 (31–83) 60% F | Surgery: 89% XRT: 74% Immuno/hormonal treatment: 9% 1 prior chemo: 18% 2 prior chemo: 42% ≥ 3 prior chemo: 40% | Adeno 61% Squamous 16% Large cell 19% Undiff 4% | IIIB: 16% IV: 84% | NR | NR | Erlotinib 150 mg | 1. Response rate 2. SD, duration of response, TTP, overall and 1-yr survival, QoL (EORTC QLQ-C30 v 3.0 & EORTC QLQ-LC13), safety
Cappuzzo et al., 2004^45^ | 40 pts 74 (70–88) 18% F | 1 prior chemo: 53% 2 prior chemo: 40% ≥ 3 prior chemo: 7.5% Chemo included platinum: 48% | Squamous 35% Adeno 45% BAC 10% NSCLC undiff 10% | IIIB: 27.5% IV: 72.5% | 0: 25% 1: 67.5% 2: 7.5% | NR | Gefitinib 250 mg | Response: RECIST Toxicity: NCI CTC 2.0
Barlesi et al., 2005^46^ | 51 pts 60 (38–78) 31%F | 2 prior chemo 60% 3 prior chemo 29% ≥4 prior chemo 12% | Adeno 47% Squamous 29% Large cell 24% | IIIb 26% IV 74% | 0/1 72% ≥2 28% | Current or former 100% | Gefitinib dose NR | Survival Response Toxicity
Felip et al., 2005^28^ | 59 pts 56 (35–78) 29%F | NR | Adeno 49% Large cell 32% Squamous 17% Other 3% | NR | NR | NR | Erlotinib 150 mg | Response Toxicity

Abbreviations: Adeno = adenocarcinoma; BAC = bronchoalveolar carcinoma; chemo = chemotherapy; EORTC QLQ-C30 = European Organization for Research and Treatment of Cancer Quality of Life Questionnaire; EORTC QLQ-LC13 = European Organization for Research and Treatment of Cancer Quality of Life Questionnaire Lung Cancer Module; NCI CTC = National Cancer Institute Common Toxicity Criteria; EGFR-TK = epidermal growth factor receptor tyrosine kinase; F = female; FACT-L = Functional Assessment of Cancer Therapy-Lung; ISEL = Iressa Survival Evaluation in Lung cancer trial; LCS = Lung Cancer Symptom Scale; NCI CTC = National Cancer Institute Common Toxicity Criteria; No. = number; NR = not reported; PFS = progression-free survival; PS = performance status; pts = patients; QoL = quality of life; RECIST = Response Evaluation Criteria in Solid Tumors; SD = stable disease; TTP = time to progression; undiff = undifferentiated; WHO = World Health Organization; XRT = radiation therapy

Table 8 Summary of tumor response in studies of second-line treatment with EGFR-TK inhibitors for advanced NSCLC

Study ID | Diagnosis (no. of patients) | Sub-groups | N | Tumor response
Study ID | Diagnosis (no. of patients) | Sub-groups | N
Study ID | Diagnosis (no. of patients) | Sub-groups | N | % CR | % PR | % SD | % DP | % NE
Phase III
Shepherd et al., 2004^24,25^ | NSCLC (~750) | Placebo Erlotinib | 211 427 | < 1 1 | < 1 8 | 27 35 | 57 38 | 15 18
ISEL press release, 2004^26^ | NSCLC (1692) | Placebo Gefitinib | NR NR | - | - 8.2 | Better in drug arm^*^ | Better in drug arm^*^ | -
Phase II
Kris et al., 2003^29^ | NSCLC (216) [Gefitinib] | 250-mg dose 500-mg dose | 102 114 | 0 0 | 12 9 | - - | - - | - -
Fukuoka et al., 2003^30^ | NSCLC (210) [Gefitinib] | 250-mg dose 500-mg dose | 104 106 | 0 1 | 18.5 18.1 | 35.9 32.4 | 40.8 41.9 | 4.9 6.7
Perez-Soler et al., 2004^31^ | NSCLC (57) [Erlotinib] | - | 57 | 3.5 | 8.8 | 35.1 | 49.1 | 3.5
Cappuzzo et al., 2004^45^ | NSCLC (40) [Gefitinib] | - | 40 | 2.5 | 2.5 | 45 | - | -
Barlesi et al., 2005^46^ | NSCLC (51) [Gefitinib] | - | 51 | 0 | 11.7 | 58.9 | - | -
Felip et al., 2005^28^ | NSCLC (59) [Erlotinib] | - | 52 | 0 | 10 | 36 | 48 | 3

* Quantitative data not reported in available data (AstraZeneca press release on ISEL study).

Abbreviations: CR = complete response; DP = disease progression; EGFR-TK = epidermal growth factor receptor tyrosine kinase; ISEL = Iressa Survival Evaluation in Lung cancer trial; NE = not evaluable; NSCLC = non-small cell lung cancer; no. = number; PR = partial response; SD = stable disease

Table 9 Summary of survival in studies of second-line treatment with EGFR inhibitors for advanced NSCLC

Study ID | Diagnosis (no. of patients) | Sub-groups | Survival from start of treatment | | | Progression-free survival
Study ID | Diagnosis (no. of patients) | Sub-groups
Study ID | Diagnosis (no. of patients) | Sub-groups | Median (months) | 1-year (%) | HR (95% CI) [p-value] | Median TTP (months) | 1-year (%) | HR (95% CI) [p-value]
Phase III
Shepherd et al., 2004^24,25^ | NSCLC (~750) | Placebo Erlotinib | 4.7 6.7 | 22 31 | 0.70 (0.58–0.85) [p = 0.001] | 1.8 2.2 | - - | 0.61 (0.51–0.74) [p < 0.001]
ISEL press release, 2004^26^ | NSCLC (1692) | Placebo - all Gefitinib - all Placebo - adeno Gefitinib - adeno | 5.1 5.6 5.4 6.3 | - - - - | 0.89 [p = 0.11] 0.83 [p = 0.07] | - - - - | - - - | - -
Phase II
Kris et al., 2003^29^ | NSCLC (216) [Gefitinib] | 250-mg dose 500-mg dose | 7 6 | 27 25 | - | - - | - - | -
Fukuoka et al., 2003^30^ | NSCLC (210) [Gefitinib] | 250-mg dose 500-mg dose | 7.6 8 | 35 29 | - | 2.7 2.8 | - - | -
Perez-Soler et al., 2004^31^ | NSCLC (57) [Erlotinib] | - | 8.4 | 40 | - | 2.1 | - | -
Cappuzzo et al., 2004^45^ | NSCLC (40) [Gefitinib] | - | 5 | - | - | 3 | - | -
Barlesi et al., 2005^46^ | NSCLC (51) [Gefitinib] | - | 4 | - | - | - | - | -

Abbreviations: adeno = adenocarcinoma; EGFR = epidermal growth factor receptor; HR = hazard ratio; ISEL = Iressa Survival Evaluation in Lung cancer trial; no. = number; NSCLC = non-small cell lung cancer; TTP = time to progression

Of six prospective phase II studies of EGFR-TK inhibitors in patients with advanced, previously treated NSCLC, four used gefitinib and two erlotinib (Table 7). Patients in two gefitinib studies were randomized to either 250 mg or 500 mg daily, while the third used only the 250 mg dose. Response rates were not significantly higher in the 500mg arms (Table 8). For the 250mg dose arms, objective response rates were 12 percent and 18.5 percent in the randomized dose comparisons, and 5 percent, 10 percent and 12 percent in the other phase II trials. Median survival was 7 and 8 months in the two larger studies, compared to 5 and 4 months in the others (not reported in one). The lower response rates in the latter studies suggest that patient selection may contribute to observed tumor response (Table 9). The two phase II studies of erlotinib found objective response rates of 10 percent and 12.3 percent.27,28 One erlotinib study required patients to have tumor samples that expressed EGFR, while the other, like the phase II gefitinib studies, did not. In this study of 57 patients,27 a response rate of 12.3 percent and median survival of 8.4 months was similar to those in the larger gefitinib studies.

### Quality of life

Quality of life data were reported for some of the clinical trials of EGFR-TK inhibitors (Table 10). The only controlled trial demonstrated a significant average improvement in quality of life symptom measures associated with erlotinib versus placebo24,25 Other data on erlotinib and all data on gefitinib are uncontrolled.29–31

Table 10 Quality-of-life outcomes in patients undergoing second-line treatment for advanced NSCLC

Study ID | No. of patients, age (median [range]), sex | Treatment (dosage/day) | QoL instrument(s) | QoL outcomes | | QoL conclusions
Phase III
Shepherd et al., 2004^24,25^ | 731 pts 62 (NR) 35% F | Erlotinib 150 mg | TTDS | TTDS-cough TTDS-dyspnea TTDS-pain | 4.9 vs. 3.7 (p = 0.04) 4.7 vs. 2.9 (p = 0.03) 2.8 vs. 1.9 (p = 0.04) | Erlotinib significantly better than placebo for improvement in TTDS-cough, TTDS-dyspnea, and TTDS-pain
Phase II
Kris et al., 2003^29^ | 216 pts 61 (30–84) 46%F | Gefitinib 250 mg Gefitinib 500 mg | LCS of FACT-L (improved indicates ≥ 2 point improvement on 28-point scale) | | 43% improved 35% improved | In both dosage arms, symptom improvement better in PR (96%) vs. SD (73%) vs. PD (17%); adeno vs. other (43% vs. 30%)
Fukuoka et al., 2003^30^ | 209 pts 61 (28–85) 29% F | Gefitinib 250 mg Gefitinib 500 mg | LCS of FACT-L (improved indicates ≥ 2 point improvement on 28-point scale) TOI FACT-L | LCS-FACT-L 7d TOI q28d FACT-L q28d LCS-FACT-L 7d TOI q28d FACT-L q28d | 40.8% 20.9% (11.9 – 32.6) 23.9% (14.3 – 25.9) 37% 17.8% (9.8 – 28.5) 21.9% (13.1 – 33.1) | Gefitinib at either dose associated with measurable improvements compared with baseline in 3 different QoL measures
Perez-Soler, et al., 2004^31^ | 57 pts 62 (31–83) 60% F | Erlotinib 150 mg | EORTC QLQ-C30 and LC13 administered at baseline, every 2 weeks for 2 months, then every month | Fatigue subscale Dyspnea subscale Cough subscale | 67% to 49% 61% to 37% 60% to 39% | Erlotinib associated with measurable improvements compared with baseline in 3 different QoL symptom measures
Comparator studies
Hanna et al., 2004^32^ | | Permetrexed Docetaxel | ASBI of LCSS | | 21.2% (p = NS) 21.5% | Both arms with similar rates of improvement, stabilization, and worsening of symptoms
Shepherd et al., 2000^33^ as reported in Dancey et al., 2004^47^ | 204 pts 61 (28–77) 35% F | BSC Docetaxel combined BSC Docetaxel combined | LCSS EORTC QLQ-C30 instrument with the LC13 lung cancer module | Patient (10 items) Observer (7 items) Pain/PF/GH | Significant difference for 1 (pain) of 17 items -19/-27/-27 -12/-19/-21 (change in subscale scores for pain/PF/GH) | Second-line docetaxel therapy for advanced NSCLC shows a trend (not statistically significant) towards less deterioration in QoL compared with BSC (in this trial that showed a statistically significant survival benefit)

Abbreviations: ASBI = Average Symptom Burden Index; BSC = best supportive care; EORTC QLQ-C30 = European Organization for Research and Treatment of Cancer Quality of Life Questionnaire; FACT-L = Functional Assessment of Cancer Therapy-Lung; GH = general health subscale; LCS or LCSS = Lung Cancer Symptom Scale; PF = physical functioning subscale

No studies directly compared quality of life outcomes associated with EGFR-TK treatment to those associated with cytotoxic chemotherapy; however, two controlled trials suggest that improvements in quality of life measures can also occur with pemetrexed or docetaxel regimens.32,33 However, while the majority of patients in the pemetrexed and docetaxel arms were stable or improved, the proportions worsening (33 percent and 27.9 percent) exceeded the proportions that improved (21.2 percent and 21.6 percent) in each arm.32 Based on these data, this study would likely not show average improvement in quality of life. Shepherd et al.,33 using the EORTC QLQ-C30 instrument with the LC13 lung cancer module, a disease-specific quality of life measure, found a trend toward less deterioration in quality of life measures associated with docetaxel than with best supportive care; however, this effect was not statistically significant. The sparse data on quality of life outcomes, the wide variety of quality of life measures, and the lack of direct comparative trials makes the comparison between gefitinib and docetaxel in terms of quality of life outcomes uncertain.

Efficacy data are available for studies of other cytotoxic chemotherapies in previously treated patients with NSCLC (Table 11). Docetaxel has been shown to have survival advantage over best supportive care33 and over vinorelbine or ifosfamide,34 with identical survival outcomes to pemetrexed.32 No prospective clinical trial data (phase III or phase II) are available for any treatments beyond second-line. Massarelli et al.35 describe similar survival associated with various third- and fourth-line chemotherapy regiments in a small retrospective study.

Table 11 Summary of survival in second-line (or higher) treatment with cytotoxic chemotherapy for advanced NSCLC

Study ID | Diagnosis (no. of patients) | Sub-groups | Survival from start of treatment | | | Progression-free survival
Study ID | Diagnosis (no. of patients) | Sub-groups
Study ID | Diagnosis (no. of patients) | Sub-groups | Median (months) | 1-year (%) | HR (95% CI) [p-value] | Median TTP (months) | 1-year (%) | HR (95% CI) [p-value]
Phase III
Shepherd et al., 2000^33^ | NSCLC (204) | BSC Docetaxel 75 mg/m^2^ Docetaxel 100 mg/m^2^ | 4.6 7.5 5.9 | - - - | p = 0.010 p = 0.047 | - - - | - - - | - -
Fossella et al., 2000^34^ | NSCLC (358) | Vinorelbine 30 mg/m^2^ or ifosfamide 2 mg/m^2^ Docetaxel 75 mg/m^2^ Docetaxel 100 mg/m^2^ | 5.4 5.8 6.6 | 10 32 32 | p = 0.001 p = 0.002 | 7.9^*^ 8.5^*^ 8.4^*^ | - - - | p = 0.093 p = 0.046
Hanna et al., 2004^32^ | NSCLC (571) | Pemetrexed 500 mg/m^2^ Docetaxel 75 mg/m^2^ | 8.3 7.9 | 30 30 | 0.99 | 2.9 2.9 | - - | 0.97 [p = 0.76]
Retrospective
Massarelli et al., 2003^35^ | NSCLC 43 pts 14 pts | Various regimens 3^rd^ line 4^th^ line | 5.4 5.9 | - - | - - | - - | - - | -

* Fossella et al. (2000)34 reported time to progression (TTP) in patients who were censored at the time of administration of subsequent therapy, which is why the TTP is longer than median survival.

Abbreviations: BSC = best supportive care; CI = confidence interval; HR = hazard ratio; no. = number; NR = not reported; NSCLS = non-small cell lung cancer; TP = time to progression

These trials of traditional chemotherapy have similar inclusion criteria and similar demographic characteristics to Shepherd et al.25 (erlotinib vs. placebo), but tend to have fewer patients with PS≥2 (ranging from 11 percent to 24 percent vs. 35 percent) and fewer patients with ≥ 2 prior chemotherapy regimens (ranging from 25 percent to 35 percent vs. 49 percent). The ISEL study (gefitinib vs. placebo) is not reported in sufficient detail to evaluate the comparability of the patient populations. The differences noted might lead one to expect slightly poorer survival in the EGFR-TK trials as compared to these second- and third-line chemotherapy trials; however, such indirect comparisons are subject to biases (due to unmeasured or unreported factors) that may be greater than the effects of the variables noted.

## Adverse Effects/Harms

Adverse effects associated with EGFR-TK inhibitors and comparison treatments are described in Table 12. The most common adverse effects of EGFR-TK inhibitors are skin toxicity and diarrhea. The skin toxicity is predominantly rash and to a lesser extent acne, pruritus, and other dermatologic reactions. For gefitinib, toxicity was more common at the higher 500 mg daily dose. Approximately half to two-thirds of patients experienced rash, and about half had diarrhea with gefitinib 250 mg. Erlotinib toxicity was somewhat more common than gefitinib toxicity; however, estimates of erlotinib toxicity are based on the results of the single published phase II trial.31 For both drugs, less than 5 percent of toxicity was grade 3 or higher. Other consistently reported toxicity included hypertransaminasemia (2 percent to 12 percent) and an uncommon interstitial lung toxicity (< 1% percent). These toxicities compare favorably to those of traditional cytotoxic agents.

Table 12 Percentages of patients reporting adverse events by treatment, dose, and grade^*^

| Gefitinib single-agent | | | | Gefitinib combined with chemotherapy | | | | Erlotinib^†^ | | Cytotoxic chemotherapy^‡^
| 500 mg/day | | 250 mg/day | | 500 mg/day | | 250 mg/day | | 150 mg/day
Adverse event | Gr 1–2 | Gr 3–4 | Gr 1–2 | Gr 3–4 | Gr 1–2 | Gr 3–4 | Gr 1–2 | Gr 3–4 | Gr 1–2 | Gr 3–4 | Gr 1–2 | Gr 3–4
Skin
Rash | 62–70 | 5–7 | 46–60 | 0–2 | 44–62 | 12–13 | 41–56 | 3–4 | 65–67 | 2–9 | 5–13 | 1
Acne | 12 | 2 | 13 | 0 | 22 | 5 | 20 | 1 | - | - | - | -
Pruritus | 35 | 1 | 30 | 0 | 11–18 | 2 | 8–14 | 0–1 | 32 | 4 | - | -
Digestive
Diarrhea | 51–70 | 5–7 | 8–56 | 0–6 | 39–44 | 12–25 | 25–48 | 4–10 | 49–54 | 1–6 | 21–34 | 2–4
Anorexia | 18 | 1 | 6–10 | 0–4 | 5–11 | 1–2 | 5–6 | 1 | 20 | 4 | - | -
Nausea/vomiting | - | - | 19 | 2–9 | - | - | - | - | 22 | 3 | - | -
Nausea | - | - | 3–22 | 0–1 | 15 | 4 | 15–17 | 2–3 | 25 | 0 | 15–32 | 2–6
Vomiting | 20 | - | 6–13 | - | 10–12 | 3–5 | 10–11 | 2–3 | 20 | 0 | 11–25 | 1–7
Stomatitis | - | - | - | - | - | - | - | - | 16 | <1–2 | 16–34 | 1–4
Hematologic
Anemia | - | - | 9–12 | 2 | 3–6 | 1–3 | 2–6 | 1–2 | - | - | - | 4–16
Neutropenia | - | - | 2–3 | - | - | 5–6 | - | 6–7 | - | - | - | 31–86
Thrombocytopenia | - | - | 4 | - | - | - | - | - | - | - | - | 1–2
Metabolic
Hypertransaminasemia | 18–20 | 3–6 | 2–12 | 0–6 | - | - | - | - | - | 0 | 1–8 | 0–2
Neurological
Alteration to CNS and | - | - | 4 | 1 | - | - | - | - | - | - | - | -
PNS
Paresthesia | - | - | - | - | - | - | - | - | 11 | 0 | - | -
Neuropathy | - | - | - | - | 3 | 1 | 5 | 1 | - | - | - | -
Neuromotor | - | - | - | - | - | - | - | - | - | - | 12–15 | 1–4
Neurosensory | - | - | - | - | - | - | - | - | - | - | 16–18 | 20–37
Whole body
Fatigue | - | - | 6 | - | - | - | - | - | 25–60 | 4–19 | 29 | 5
Pain | 16 | - | 10 | - | - | - | - | - | 12 | 2 | - | -
Asthenia | 8 | 1 | 6–7 | 0–2 | 9 | 2 | 8–13 | 1–2 | | | 19–41 | 11–28
Anxiety | - | - | - | - | - | - | - | - | 18 | 4 | - | -
Insomnia | - | - | - | - | - | - | - | - | 10 | 2 | - | -
Weight loss | - | - | 1 | - | - | - | - | - | 12 | 0 | - | -
Dehydration | - | - | - | - | 5 | 5 | 2 | 2 | 3 | 3–4 | - | -
Pulmonary | | | | | | | | | | | 16–20 | 20–37
Dyspnea | - | - | - | - | - | - | - | - | 17 | 4 | - | -
Cough | - | - | - | - | - | - | - | - | 16 | 0 | - | -
Pneumonitis or pulmonary infiltrates | - | - | - | - | - | - | - | - | 3 | <1 | - | -
Musculoskeletal
Arthralgia | - | - | - | - | - | - | - | - | 14 | 0 | - | -
Ocular | | | | | | | | | 27 | 1
Conjunctivitis | - | - | 1.3 | - | 5–6 | 0–1 | 1–5 | 0–1 | - | - | - | -
Infection | - | - | - | - | - | - | - | - | 32 | 2 | 16–25 | 5–14
Cardiac | - | - | - | - | - | - | - | - | - | - | 7–12 | 2–4

* Cells show single value if only one study contributed data, and a range if more than one study contributed data.

† Data on erlotinib are from Perez-Soler et al. (2004),31 Shepherd et al. (2005)25, and Jackman et al. (2005)21

‡ Chemotherapy studies include studies of docetaxel 75 mg32–34 and 100 mg;33,34 venlafaxine or ifosfamide;34 and pemetrexed.32

Abbreviations: CNS = central nervous system; Gr = grade; PNS = peripheral nervous system

## Predictors of Response

All reports on predictors of response or survival from EGFR-TK inhibitor clinical studies are shown in Tables 13 and 14. Predictors of response to EGFR-TK inhibitors were distinguished from prognostic factors, which are associated with survival. The latter were not of primary interest for this report, as the prognostic factors reported in the examined studies have generally been known for decades and are not specific to EGFR-TK inhibitors. Response predictors considered were predictors of a higher likelihood of objective tumor response (in phase II and phase III studies) or identifiers of a subgroup with differential treatment effect (for phase III studies). Clinical factors reported as being tested for association with either response or survival are shown in Table 13. Those characteristics that were initially identified as associated with a higher response rate in more than two studies included female sex and never smoking status. Studies examining the association between these factors and response are detailed in Table 15. For sex, there is a consistent association between female sex and a doubled likelihood of response. For smoking, the effect is less consistent between studies but is, on average, stronger than that observed for sex.

Table 13 Patient characteristics predictive of survival, TTP, or response among EGFR inhibitor studies

Characteristic | Favorable prognostic factor | No. of studies indicating an association with response | References | No. of studies indicating an association with survival | References
Sex | Female vs. male | 7/13 | 13,25,29–31,38,48–54 | 4/7 | 18,25,38,55–58
Performance status | PS 0/1 vs. PS 2 or KPS ≥ 80 vs. ≤ 70 | 1/7 | 13,25,29,30,53,59,60 | 10/11 | 6,7,25,31,54,56,56,57,61–63
Smoking status | Never vs. former/current | 11/15 | 13,19,25,38,48–53,60,63–66 | 6/7 | 8,25,26,38,61,65,67
Prior chemo | Yes vs. no or number of prior regimens | 1/6 | 29,31,52,53,59,66 | - | -
Age | > 70 vs. ≤ 70 years | 2/6 | 25,29,31,60,66,68 | 0/2 | 25,68
Rash | Any vs. none | 0/3 | 31,38,48 | 7/8 | 6,18,31,38,46,57,62,69
Stage of disease | IIIB vs. IV | 0/3 | 13,31,59 | 1/1 | 55
| I–IV vs. recurrent | 0/1 | 60 | - | -
Ethnicity | East Asian vs. non-East Asian | 2/3 | 25,30,66 | 3/3 | 25,26,55
Prior immuno/hormonal therapy | Yes vs. none | 1/1 | 30 | - | -
Hypertransaminasemia | | 1/1 | 38 | 1/1 | 38
Bone or liver metastasis | | 0/1 | 53 | 2/2 | 6,7
Pulmonary metastases | > 6 vs. ≤ 6 | 1/1 | 64 | - | -
Brain metastases | | 0/1 | 60 | - | -
Prior XRT to chest | No vs. yes | 1/1 | 38 | - | -
Prior cisplatin or carboplatin | Yes vs. no | 0/2 | 25,53 | 0/1 | 25
Prior docetaxel | Yes vs. no | 0/1 | 53 | - | -
Time since last chemo | < 6 vs. ≥ 6 mo | 1/1 | 31 | - | -
Time since diagnosis | - | 0/1 | 29 | 1/1 | 31
Weight loss | - | - | - | 2/2 | 6,7
Diarrhea | - | - | - | 1/1 | 38

Abbreviations: chemo = chemotherapy; EGFR = epidermal growth factor receptor; KPS = Karnofsky performance status; No. = number; PS = performance status; TTP = time to progression; XRT = radiation therapy

Table 14 Tumor characteristics predictive of response or survival among EGFR-TK inhibitor studies^*^

Characteristic | Favorable prognostic factor | No. of studies indicating an association with response | References | No. of studies indicating an association with survival | References
Histologic type | Adeno vs. non-adeno | 10/17 | 13,25,29,42,48,49,70 | 4/4 | 25,38,42,57
Histologic type | BAC vs. non-BAC | 2/4 | 50,71
Histologic type | Adeno/BAC vs. adeno, non-BAC vs. other | 2/2 | 53,56 | 1/1 | 56
Histologic type | Papillary vs. non- papillary | 1/1 | 72 | 1/1 | 72
Grade | Well/moderately vs. poorly differentiated | | | 2/2 | 54,73
Stromal invasion | | | | 1/1 | 73
Mucin production | | | | 1/1 | 73
Expression by IHC
EGFR | Low vs. high | 4/12 | 25,31,50,52,65,72,74–79 | 3/4 | 25,50,73,74
HER2/erbB2 | 2+/3+ vs. 0/1+ | 2/6 | 50,65,70,72,78,80 | 1/2 | 73,80
p-EGFR | - | 0/4 | 52,65,72,76 | 0/1 | 81
p-Akt status | Positive vs. negative | 2/6 | 50–52,63,65,78 | 1/3 | 50,67,70
p-Erk/p-MAPK | 2+/3+ vs. 0/1+ | 3/6 | 50–52,63,65,76 | 1/1 | 73
p-STAT3 | | 0/1 | 52
P53 | | 0/1 | 78
Ki-67 | | 1/1 | 65 | 2/2 | 65,73
CYFRA 21-1 | > 3.5 ng/ml vs. ≤ 3.5 ng/ml | - | | 1/2 | 46,67
EGFR mutation | Mutation vs. wild type | 19/23 | 13,21,42,48–51,66,70,82–93 | 7/11 | 13,42,50,66,67,70,87,89,92,93
KRAS mutation | Mutation vs. Wild type | 1/3 | 21,36,89 | 0/2 | 89,94

* Results of multivariable analysis reported in preference to results of univariable analyses when both were available.

Abbreviations: Adeno = adenocarcinoma; Adeno/BAC = adenocarcinoma with bronchoalveolar carcinoma features; BAC = bronchoalveolar carcinoma; EGFR = epidermal growth factor receptor; EGFR-TK = epidermal growth factor receptor tyrosine kinase; IHC = immuno histochemistry; No. = number

Table 15 Association with response for selected predictors

Predictor (reference group) | Study | Reference group response | Comparison group response | Relative risk (95% CI)
Sex (women vs. men) | Kris et al., 2003^29^ | 18/93 | 4/123 | 6.0 (2.1 – 17)
Sex (women vs. men) | Fukuoku et al., 2003^30^ | 19/62 | 18/148 | 2.6 (1.2 – 5.9)
Sex (women vs. men) | Perez-Soler et al., 2004 31 | NR | NR | NR
Sex (women vs. men) | Takano et al., 2004^38^ | 17/32 | 15/66 | 2.3 (1.3 – 4.1)
Sex (women vs. men) | Han et al., 2005^51^ | 5/24 | 5/49 | 2.0 (0.7 – 6.4)
Sex (women vs. men) | Miller et al., 2004^8^ | 17/91 | 4/48 | 2.2 (0.8 – 6.3)
Sex (women vs. men) | Han et al., 2005^52^ | NR | NR | NR
Sex (women vs. men) | Matsuura et al., 2004^54^ | NR | NR | NR
Sex (women vs. men) | Kasahara et al., 2005^13^ | 6/12 | 4/18 | 2.2 (0.80 – 6.3)
Sex (women vs. men) | Kim et al., 2005^48^ | 8/19 | 12/61 | 2.0 (0.97 – 4.3)
Sex (women vs. men) | Mitsudomi et al, 2005^49^ | 15/23 | 11/27 | 2.1 (0.93 – 2.8)
Sex (women vs. men) | Tsao et al., 2005^42^ | 21/146 | 17/281 | 2.3 (1.3 – 4.4)
Smoking (never vs. current/former) | Kris et al., 2004^19^ | 7/19 | 8/40 | 1.8 (0.78 – 4.3)
Smoking (never vs. current/former) | Han et al., 2005^51^ | 7/32 | 3/41 | 3.0 (0.84 – 10)
Smoking (never vs. current/former) | Hotta et al., 2004^60^ | 7/28 | 8/28 | 0.88 (0.37 – 2.1)
Smoking (never vs. current/former) | Miller et al., 2004^53^ | 13/36 | 8/103 | 4.6 (2.1 – 10)
Smoking (never vs. current/former) | Takano et al., 2004^38^ | 20/32 | 12/60 | 3.1 (1.8 – 5.5)
Smoking (never vs. current/former) | Han et al., 2005^52^ | NR | NR | NR
Smoking (never vs. current/former) | Cappuzzo et al., 2004^63^ | NR | NR | NR
Smoking (never vs. current/former) | Kasahara et al., 2005^13^ | 5/10 | 5/20 | 2.0 (0.75 – 5.3)
Smoking (never vs. current/former) | Kim et al., 2005^48^ | 10/17 | 10/63 | 3.7 (1.9 – 7.4)
Smoking (never vs. current/former) | Kishi et al., 2005^65^ | NR | NR | P=0.0006
Smoking (never vs. current/former) | Mitsudomi et al, 2005^49^ | 17/25 | 9/25 | 1.9 (1.0 – 3.4)
Smoking (never vs. current/former) | Taron et al., 2005^66^ | NR | NR | P<0.05
Smoking (never vs. current/former) | Tsao et al., 2005^42^ | 23/93 | 12/311 | 6.4 (3.3 – 12)
Smoking (never vs. current/former) | Villaflor et al., 2005^70^ | 7/20 | 5/130 | 9.1 (3.2 – 26)

* As reported from final adjusted model.

Abbreviations: CI = confidence interval; NR = not reported; OR = odds ratio; PS = performance status

Two factors had more than one study reporting an association with response: age over 70 years and East Asian ethnicity. The associations with age were not consistent in direction with some studies finding older patients more likely to respond and some studies reporting younger patients having the higher response rate. East Asian ethnicity was associated with higher responses in 2 of 3 studies reporting on this factor; this finding is consistent with data showing a higher incidence of EGFR mutation in East Asian NSCLC patients.

Two other factors have received some attention in the literature: rash and performance status. However, for rash, the associations are weak and not statistically significant in the few studies reporting on the association. Performance status is an extremely important general prognostic factor, but did not have any consistent association with likelihood of tumor response among the seven studies reporting this association.

Tumor characteristics potentially predictive of response or survival are shown in Table 14. Adenocarcinoma histology and its subtypes of BAC and papillary type were associated with better response in about half of studies. Contrary to initial expectations of many of the investigators, the majority of studies examining EGFR expression did not associate EGFR expression with response. Also, no reproducible association was found between response and the related receptor TK; Her2/neu (erbB2), which forms heterodimers with EGFR; the activated form of EGFR (p-EGFR); or the activated downstream signaling molecules (p-Akt, p-Erk/p-MAPK, and p-STAT3). In contrast, nineteen studies have found a strong positive association between presence of somatically acquired mutation of the active site of EGFR and response to gefitinib or erlotinib (Table 16). The biological plausibility of this association is strengthened by the finding of secondary mutations of EGFR in tumors from patients with secondary resistance to EGFR-TK inhibitors. Furthermore, the EGFR mutations occur preferentially in the demographic groups with highest response rates to EGFR-TK inhibitors, most notably non-smokers but also women and East Asians, as well as patients with adenocarcinoma histology. However, findings from the BR21 study of erlotinib (the only randomized trial to show an overall survival benefit from EFGR-TK inhibitors), showed no association of EGFR mutation and survival benefit. Additional molecular predictors of response and survival benefit are being investigated including EGFR gene copy number. While KRAS mutations were associated with non-response in preliminary reports, 36,37 few data are yet available to confirm this negative association with response.

Table 16 Association of EGFR mutation with response to gefitinib

Study name | Direction | Responses / Total | Responses / Total | Statistics for each study
| | Mutation | Wild type | Risk ratio | Lower limit | Upper limit | p-value
Paez et al. 2004^84^ | Case-control | 5 / 5 | 0 / 4 | 9.2 | 0.7 | 128.5 | 0.1001
Jackman et al. 2005^21^ | Cohort | 3 / 5 | 2 / 23 | 6.9 | 1.5 | 31.1 | 0.0119
Kim et al. 2005^48^ | Cohort | 6 / 6 | 2 / 21 | 8.2 | 2.5 | 26.7 | 0.0005
Pao et al. 2004^83^ | Case-control | 7 / 7 | 3 / 8 | 2.4 | 1.0 | 5.6 | 0.0397
Huang et al. 2004^85^ | Case-control | 7 / 8 | 2 / 8 | 3.5 | 1.0 | 12.0 | 0.0456
Lynch et al. 2004^82^ | Case-control | 8 / 8 | 1 / 8 | 5.7 | 1.3 | 24.6 | 0.0207
Kawada et al. 2005^90^ | Cohort | 8 / 8 | 1 / 13 | 8.8 | 1.9 | 40.3 | 0.0050
Tokumo et al. 2005^86^ | Case-control | 8 / 9 | 2 / 12 | 5.3 | 1.5 | 19.3 | 0.0107
Cortes-Funes et al. 2005^87^ | Cohort | 8 / 10 | 6 / 73 | 9.7 | 4.3 | 22.3 | 0.0000
Fujiwara et al. 2005^95^ | Cohort | 7 / 11 | 3 / 15 | 3.2 | 1.1 | 9.6 | 0.0403
Kris et al. 2005^91^ | Cohort | 10 / 13 | 3 / 37 | 9.5 | 3.1 | 29.2 | 0.0001
Han et al. 2005 (2)89 | Cohort | 8 / 13 | 6 / 46 | 4.7 | 2.0 | 11.2 | 0.0004
Lynch (IDEAL) 2005^92^ | Cohort | 6 / 13 | 6 / 61 | 4.7 | 1.8 | 12.3 | 0.0016
Kasahara et al. 2005^13^ | Cohort | 12 / 14 | 4 / 13 | 2.8 | 1.2 | 6.5 | 0.0172
Villaflor et al. 2005^70^ | Cohort | 9 / 14 | 3 / 44 | 9.4 | 3.0 | 30.1 | 0.0002
Taron et al. 2005^66^ | Cohort | 16 / 17 | 6 / 51 | 8.0 | 3.7 | 17.1 | 0.0000
Han et al. 2005^51^ | Cohort | 11 / 17 | 10 / 73 | 4.7 | 2.4 | 9.3 | 0.0000
Lynch (INTACT) 2005^92^ | Cohort | 13 / 18 | 84 / 152 | 1.3 | 0.9 | 1.8 | 0.1014
Tsao (BR.21) 2005^42^ | Cohort | 3 / 19 | 6 / 81 | 2.1 | 0.6 | 7.8 | 0.2512
Mitsudomi et al. 2005^49^q | Cohort | 24 / 29 | 2 / 21 | 8.7 | 2.3 | 32.8 | 0.0014
Tsai et al. 2005^93^ | Cohort | 22 / 29 | 10 / 25 | 1.9 | 1.1 | 3.2 | 0.0163
Takano et al. 2005^50^ | Cohort | 33 / 39 | 3 / 27 | 7.6 | 2.6 | 22.3 | 0.0002