# References

1 Jemal A, Murray T, Ward E, et al. Cancer statistics, 2005. Ca: a Cancer Journal for Clinicians. 2005;55(1):10-30. [pmid: 15661684].
2 Pfister DG, Johnson DH, Azzoli CG, et al. American Society of Clinical Oncology treatment of unresectable non-small-cell lung cancer guideline: update 2003. Journal of Clinical Oncology. 2004;22(2):330-353. [pmid: 14691125].
3 Socinski MA, Morris DE, Masters GA, et al. Chemotherapeutic management of stage IV non-small cell lung cancer. Chest. 2003;123(1 Suppl):226S-243S. [pmid: 12527582].
4 Robinson KA, Dickersin K. Development of a highly sensitive search strategy for the retrieval of reports of controlled trials using PubMed. International Journal of Epidemiology. 2002;31(1):150-153. [pmid: 11914311].
5 Wilson JS, Connock M, Song FJ, et al. Imatinib mesylate for the treatment of patients with unresectable and/or metastatic gastrointestinal stromal tumours (GIST). Health Technology Assessment. 2003.
6 Herbst RS, Giaccone G, Schiller JH, et al. Gefitinib in combination with paclitaxel and carboplatin in advanced non-small-cell lung cancer: a phase III trial―INTACT 2. Journal of Clinical Oncology. 2004;22(5):785-794. [pmid: 14990633].
7 Giaccone G, Herbst RS, Manegold C, et al. Gefitinib in combination with gemcitabine and cisplatin in advanced non-small-cell lung cancer: a phase III trial―INTACT 1. Journal of Clinical Oncology. 2004;22(5):777-784. [pmid: 14990632].
8 Miller VA, Herbst RS, Prager D, et al. Long survival of never smoking non-small cell lung cancer (NSCLC) patients (pts) treated with erlotinib HCl (OSI-774) and chemotherapy: Sub-group analysis of TRIBUTE. Journal of Clinical Oncology. 2004;22(14S):7061.
9 Gatzemeier U, Pluzanska A, Szczesna A, et al. Results of a phase III trial of erlotinib (OSI-774) combined with cisplatin and gemcitabine (GC) chemotherapy in advanced non-small cell lung cancer (NSCLC). Journal of Clinical Oncology. 2004;22(14S):7010.
10 Williams CC, Haura EB, Antonia SJ, et al. Phase II trial of docetaxel and gefitinib as first-line therapy for elderly patients with advanced nonsmall cell lung cancer (ANSCLC). Journal of Clinical Oncology. 2004;22(14S). Abstract #7342.
11 Niho S, Kubota K, Goto K, et al. First-line single agent of gefitinib in patients (pts) with advanced non-small cell lung cancer (NSCLC): A phase II study. Journal of Clinical Oncology. 2004;22(14):059.
12 Giaccone G, Lechevalier T, Thatcher N, et al. A phase II study of Erlotinib as first-line treatment of advanced non-small cell lung cancer. 2005 ASCO Annual Meetings. 2005. Abstract #7073.
13 Kasahara K, Kimura H, Yoshimoto A, et al. A phase II study of gefitinib monotherapy for chemotherapy-naive patients with non-small cell lung cancer. 2005 ASCO Annual Meetings. 2005. Abstract #7074.
14 Suzuki R, Hasegawa Y, Baba K, et al. A phase II study of first-line single agent of gefitinib in patients (pts) with stage IV non-small cell lung cancer (NSCLC). 2005 ASCO Annual Meetings. 2005. Abstract #7082.
15 Reck M, Gatzemeier U, Bucholz E, et al. An open-label, multi centre, phase II, non-comparative trial of ZD1839 monotherapy in chemotherapy-naive patients with stage IV or stage III non-operable non-small cell lung cancer (NSCLC). 2005 ASCO Annual Meetings. 2005. Abstract #7098.
16 D'Addario G, Rauch D, Stupp R, et al. Multicenter phase II trial of gefitinib first-line therapy followed by chemotherapy in advanced non-small cell lung cancer (NSCLC) - preliminary results. A study of the Swiss Group for Clinical Cancer Research (SAKK). 2005 ASCO Annual Meetings. 2005. Abstract #7128.
17 Lee DH, Han JY, Lee HG, et al. A phase II study of gefitinib as a first-line therapy of advanced or metastatic adenocarcinoma of the lung in lifetime non-smokers. 2005 ASCO Annual Meetings. 2005. Abstract #7072.
18 West H, Franklin WA, Gumerlock PH, et al. Gefitinib (ZD1839) therapy for advanced bronchioloalveolar lung cancer (BAC): Southwest Oncology Group (SWOG) Study S0126. Journal of Clinical Oncology. 2004;22(14):014.
19 Kris MG, Sandler A, Miller V, et al. Cigarette smoking history predicts sensitivity to erlotinib: Results of a phase II trial in patients with bronchioloalveolar carcinoma (BAC). Journal of Clinical OncologY. 2004;22(14):062.
20 Johnson BE, Lucca J, Rabin MS, et al. Preliminary results from a phase II study of the epidermal growth factor receptor tyrosine kinase inhibitor erlotinib in patients > 70 years of age with previously untreated advanced non-small cell lung carcinoma. Journal of Clinical Oncology. 2004;22(14):080.
21 Jackman D, Lucca J, Fidias P, et al. Phase II study of the EGFR tyrosine kinase erlotinib in patients > 70 years of age with previously untreated advanced non-small cell lung carci. 2005 ASCO Annual Meetings. 2005. Abstract #7148.
22 Dickson NR, Hainsworth JD, Spigel DR, et al. Single agent gefitinib in poor performance status patients with previously untreated advanced nonsmall cell lung cancer: A Minnie Pearl Cancer Research Network phase II trial. Journal of Clinical Oncology. 2004;22(14):086.
23 Reiling RB, Natale R, Wade J, et al. Efficacy and safety of gefitinib in chemo-naive patients with non-small cell lung cancer (NSCLC) in an Expanded Access Program (EAP). 2005 ASCO Annual Meetings. 2005. Abstract #22650.
24 Shepherd FA, Pereira J, Ciuleanu TE, et al. A randomized placebo-controlled trial of erlotinib in patients with advanced non-small cell lung cancer (NSCLC) following failure of 1st line or 2nd line chemotherapy. A National Cancer Institute of Canada Clinical Trials Group (NCIC CTG) trial. Journal of Clinical Oncology. 2004;22(14S):7022.
25 Shepherd FA, Rodrigues Pereira J, Ciuleanu T, et al. Erlotinib in previously treated non-small-cell lung cancer. New England Journal of Medicine. 2005;353(2):123-132. [pmid: 16014882].
26 AstraZeneca. Gefitinib (Iressa™) lung cancer ISEL trial shows no overall survival advantage in a highly refractory population. 2004.
27 Perez-Soler R. Phase II clinical trial data with the epidermal growth factor receptor tyrosine kinase inhibitor erlotinib (OSI-774) in non-small-cell lung cancer. Clinical Lung Cancer. Suppl 1. 2004;6:S20-S23. [pmid: 15638953].
28 Felip E, Rojo F, Heller A, et al. Phase II pharmacodynamic trial of erlotinib in advanced non-small cell lung cancer (NSCLC) patients previously treated with platinum-based chemotherapy: preliminary results. 2005 ASCO Annual Meetings. 2005. Abstract #7100.
29 Kris MG, Natale RB, Herbst RS, et al. Efficacy of gefitinib, an inhibitor of the epidermal growth factor receptor tyrosine kinase, in symptomatic patients with non-small cell lung cancer: a randomized trial. JAMA. 2003;290(16):2149-2158. [pmid: 14570950].
30 Fukuoka M, Yano S, Giaccone G, et al. Multi-institutional randomized phase II trial of gefitinib for previously treated patients with advanced non-small-cell lung cancer. Journal of Clinical Oncology. 2003;21(12):2237-2246. [pmid: 12748244].
31 Perez-Soler R, Chachoua A, Hammond LA, et al. Determinants of tumor response and survival with erlotinib in patients with non--small-cell lung cancer. Journal of Clinical Oncology. 2004;22(16):3238-3247. [pmid: 15310767].
32 Hanna N, Shepherd FA, Fossella FV, et al. Randomized phase III trial of pemetrexed versus docetaxel in patients with nonsmall-cell lung cancer previously treated with chemotherapy. Journal of Clinical Oncology. 2004;22(9):1589-1597. [pmid: 15117980].
33 Shepherd FA, Dancey J, Ramlau R, et al. Prospective randomized trial of docetaxel versus best supportive care in patients with nonsmall-cell lung cancer previously treated with platinum-based chemotherapy. Journal of Clinical Oncology. 2000;18(10):2095-20103. [pmid: 10811675].
34 Fossella FV, DeVore R, Kerr RN, et al. Randomized phase III trial of docetaxel versus vinorelbine or ifosfamide in patients with advanced nonsmall-cell lung cancer previously treated with platinum-containing chemotherapy regimens. Journal of Clinical Oncology. 2000;18(12):2354-2362. [pmid: 10856094].
35 Massarelli E, Andre F, Liu DD, et al. A retrospective analysis of the outcome of patients who have received two prior chemotherapy regimens including platinum and docetaxel for recurrent non-small-cell lung cancer. Lung Cancer. 2003;39:55-61. [pmid: 12499095].
36 Pao W, Wang TY, Riely GJ, et al. KRAS mutations and primary resistance of lung adenocarcinomas to gefitinib or erlotinib. PLoS Med. 2005;2(1):e17. [pmid: 15696205].
37 Eberhard DA, Johnson BE, Amler LC, et al. Mutations in the epidermal growth factor receptor and in KRAS are predictive and prognostic indicators in patients with non–small-cell lung cancer rreated with chemotherapy alone and in combination with erlotinib. Journal of Clinical Oncology. 2005;23(25):5900-5909. [pmid: 16043828].
38 Takano T, Ohe Y, Kusumoto M, et al. Risk factors for interstitial lung disease and predictive factors for tumor response in patients with advanced non-small cell lung cancer treated with gefitinib. Lung Cancer. 2004;45(1):93-104. [pmid: 15196739].
39 AstraZeneca. Gefitinib (IRESSA™) marketing authorisation application withdrawn in EU. 2005. January. 4. Accessed at http://www.astrazeneca.com/pressrelease/4442.aspx on March 22, 2005.
40 Cappuzzo F, Varella-Garcia M, Shigematsu H, et al. Increased HER2 gene copy number is associated with response to gefitinib therapy in epidermal growth factor receptorpositive nonsmall-cell lung cancer patients. Journal of Clinical Oncology. 2005;23(22):5007-5018. [pmid: 16051952].
41 Hirsch F, Varella-Garcia M, McCoy J, et al. Increased epidermal growth factor receptor gene copy number detected by fluorescence in situ hybridization associates with increased sensitivity to gefitinib in patients with bronchioloalveolar carcinoma subtypes: a Southwest Oncology Group study. Journal of Clinical Oncology. 2005;23(28):6838-6845. [pmid: 15998906].
42 Tsao MS, Sakurada A, Cutz JC, et al. Erlotinib in lung cancer - molecular and clinical predictors of outcome. New England Journal of Medicine. 2005;353(2):133-144. [pmid: 16014883].
43 Pao W, Miller VA, Politi KA, et al. Acquired resistance of lung adenocarcinomas to gefitinib or erlotinib is associated with a second mutation in the EGFR kinase domain. PLoS Med. 2005;2(3):e73. [pmid: 15737014].
44 Kobayashi S, Boggon TJ, Dayaram T, et al. EGFR mutation and resistance of non-small-cell lung cancer to gefitinib. New England Journal of Medicine. 2005;352(8):786-792. [pmid: 15728811].
45 Cappuzzo F, Bartolini S, Ceresoli GL, et al. Efficacy and tolerability of gefitinib in pretreated elderly patients with advanced non-small-cell lung cancer (NSCLC). British Journal of Cancer. 2004;90(1):82-86. [pmid: 14710211].
46 Barlesi F, Tchouhadjian C, Doddoli C, et al. CYFRA 21-1 level predicts survival in non-small-cell lung cancer patients receiving gefitinib as third-line therapy. British Journal of Cancer. 2005;92(1):13-14. [pmid: 15597098].
47 Dancey J, Shepherd FA, Gralla RJ, et al. Quality of life assessment of second-line docetaxel versus best supportive care in patients with non-small-cell lung cancer previously treated with platinum-based chemotherapy: results of a prospective, randomized phase III trial. Lung Cancer. 2004;43:183-194. [pmid: 14739039].
48 Kim KS, Jeong JY, Kim YC, et al. Predictors of the response to gefitinib in refractory non-small cell lung cancer. Clinical Cancer Research. 2005;11(6):2244-2251. [pmid: 15788673].
49 Mitsudomi T, Kosaka T, Endoh H, et al. Mutations of the epidermal growth factor receptor gene predict prolonged survival after gefitinib treatment in patients with non-small-cell lung cancer with postoperative recurrence. Journal of Clinical Oncology. 2005;23(11):2513-2520. [pmid: 15738541].
50 Takano T, Ohe Y, Yoshida T, et al. Evaluation of epidermal growth factor receptor (EGFR) mutations and gene copy numbers as predictors of clinical outcomes in Japanese patients with recurrent non-small-cell lung cancer (NSCLC) receiving gefitinib. 2005 ASCO Annual Meetings. 2005. Abstract #7032.
51 Han SW, Kim TY, Hwang PG, et al. Predictive and prognostic impact of epidermal growth factor receptor mutation in non-small-cell lung cancer patients treated with gefitinib. Journal of Clinical Oncology. 2005;23(11):2493-2501. [pmid: 15710947].
52 Han SW, Hwang PG, Chung DH, et al. Epidermal growth factor receptor (EGFR) downstream molecules as response predictive markers for gefitinib (Iressa, ZD1839) in chemotherapy-resistant non-small cell lung cancer. International Journal of Cancer. 2005;113(1):109-115.
53 Miller VA, Kris MG, Shah N, et al. Bronchioloalveolar pathologic subtype and smoking history predict sensitivity to gefitinib in advanced non-small-cell lung cancer. Journal of Clinical Oncology. 2004;22(6):1103-1109. [pmid: 15020612].
54 Matsuura K, Kudoh S, Mitsuoka S, et al. Evaluating a prognostic factor in advanced adenocarcinoma of the lung who have treated with gefitinib. Journal of Clinical Oncology. 2004;22(14):334.
55 Ochs J, Grous JJ, Warner KL. Final survival and safety results for 21,064 non-small-cell lung cancer (NSCLC) patients who received compassionate use gefitinib in a U.S. expanded access program (EAP). Journal of Clinical Oncology. 2004;22(14):060.
56 Simon GR, Ruckdeschel JC, Williams C, et al. Gefitinib (ZD1839) in previously treated advanced non-small-cell lung cancer: experience from a single institution. Cancer Control. 2003;10(5):388-395. [pmid: 14581894].
57 Janne PA, Gurubhagavatula S, Yeap BY, et al. Outcomes of patients with advanced non-small cell lung cancer treated with gefitinib (ZD1839, "Iressa") on an expanded access study. Lung Cancer. 2004;44(2):221-230. [pmid: 15084387].
58 Wu YL, Yang X, Yang J-J, et al. ZD1839 for the treatment of heavily pretreated non-small cell lung cancer. Journal of Clinical Oncology. 2004;22(14):341.
59 Pallis AG, Mavroudis D, Androulakis N, et al. ZD1839, a novel, oral epidermal growth factor receptor-tyrosine kinase inhibitor, as salvage treatment in patients with advanced non-small cell lung cancer. Experience from a single center participating in a compassionate use program. Lung Cancer. 2003;40(3):301-307. [pmid: 12781429].
60 Hotta K, Kiura K, Ueoka H, et al. Effect of gefitinib ('Iressa', ZD1839) on brain metastases in patients with advanced non-small-cell lung cancer. Lung Cancer. 2004;46(2):255-261. [pmid: 15474674].
61 Villaflor VM, Polowy CR, Coon JS, et al. Potential clinical prognostic factors in non-small cell lung cancer (NSCLC) patients treated with gefitinib. Journal of Clinical Oncology. 2004;22(14):088.
62 Mohamed MK, Ramalingam S, Lin Y, et al. Skin rash and good performance status (PS) predict improved survival with gefitinib for patients with advanced non-small cell lung cancer (NSCLC). Journal of Clinical Oncology. 2004;22(14):097.
63 Cappuzzo F, Magrini E, Ceresoli GL, et al. Akt phosphorylation and gefitinib efficacy in patients with advanced non-small-cell lung cancer. Journal of the National Cancer Institute. 2004;96(15):1133-1141. [pmid: 15292385].
64 Goto K, Kim E, Kubota K, et al. Association of multiple pulmonary metastases with response to gefitinib in patients with non-small cell lung cancer. Journal of Clinical Oncology. 2004;22(14):098.
65 Kishi K, Homma S, Miyamoto A, et al. Factors predicting the efficacy of gefitinib in patients with advanced non-small cell lung cancer (NSCLC). 2005 ASCO Annual Meetings. 2005. Abstract #7095.
66 Taron M, Ichinose Y, Rosell R, et al. Epidermal growth factor receptor (EGFR) activating mutations (muts) in the tyrosine kinase (TK) domain correlate with gefitinib response in chemorefractory non-small-cell lung cancer (NSCLC). 2005 ASCO Annual Meetings. 2005. Abstract #7087.
67 Gatzemeier U, Heller A, Foernzler D, et al. Exploratory analyses EGFR, kRAS mutations and other molecular markers in tumors of NSCLC patients (pts) treated with chemotherapy +/- erlotinib (TALENT). 2005 ASCO Annual Meetings. 2005. Abstract #7028.
68 Gridelli C, Maione P, Castaldo V, et al. Gefitinib in elderly and unfit patients affected by advanced non-small-cell lung cancer. British Journal of Cancer. 2003;89(10):1827-1829. [pmid: 14612886].
69 Ervin TJ, Toothaker SR. Community practice experience with gefitinib (ZD1839) as treatment for patients with advanced non-small-cell lung cancer (NSCLC) within an expanded access clinical program. Journal of Clinical Oncology. 2004;22(14):367.
70 Villaflor VM, Buckingham L, Gale M, et al. EGFR mutations and pAKT expression as potential predictors of gefitinib efficacy in non-small cell lung cancer (NSCLC) patients (pts). 2005 ASCO Annual Meetings. 2005. Abstract #7077.
71 Hussain S, Zakowski MF, Kris MG, et al. Correlation of EGFR and KRAS mutation status, response to epidermal growth factor receptor (EGFR) tyrosine kinase inhibitors and survival with histologic subtypes of adenocarcinoma of the lung. 2005 ASCO Annual Meetings. 2005. Abstract #7080.
72 Kim YH, Goto K, Ishii G, et al. Association of papillary subtype of lung adenocarcinoma with response to gefitinib. Journal of Clinical Oncology. 2004;22(14):092.
73 Franklin WA, Chansky K, Gumerlock PH, et al. Association between activation of ErbB pathway genes and survival following gefitinib treatment in advanced BAC (SWOG 0126). Journal of Clinical Oncology. 2004;22(14):015.
74 Parra HS, Cavina R, Latteri F, et al. Analysis of epidermal growth factor receptor expression as a predictive factor for response to gefitinib ('Iressa', ZD1839) in non-small-cell lung cancer. British Journal of Cancer. 2004;91(2):208-212. [pmid: 15187994].
75 Bailey LR, Janas M, Schmidt K, et al. Evaluation of epidermal growth factor receptor (EGFR) as a predictive marker in patients with non-small-cell lung cancer (NSCLC) receiving first-line gefitinib combined with platinum-based chemotherapy. Journal of Clinical Oncology. 2004;22(14):013.
76 Han SW, Hwang PG, Chung DH, et al. Gefitinib monotherapy in previously treated advanced non-small cell lung cancer (NSCLC): An immunohistochemical (IHC) analysis of EGFR and its downstream molecules. Journal of Clinical Oncology. 2004;22(14):096.
77 Polowy C, Coon J, Villaflor V, et al. Potential molecular prognostic factors in non-small cell lung cancer (NSCLC) patients treated with gefitinib. Journal of Clinical Oncology. 2004;22(14):089.
78 Pao W, Zakowski M, Cordon-Cardo C, et al. Molecular characteristics of non-small cell lung cancer (NSCLC) patients sensitive to gefitinib. Journal of Clinical Oncology. 2004;22(14):025.
79 Miller VA, Zakowski M, Riely GJ, et al. EGFR mutation, immunohistochemistry (IHC) and chromogenic in situ hybridization (CISH) as predictors of sensitivity to erlotinib and gefitinib in patients (pts) with NSCLC. 2005 ASCO Annual Meetings. 2005. Abstract #7031.
80 Cappuzzo F, Gregorc V, Rossi E, et al. Gefitinib in pretreated non-small-cell lung cancer (NSCLC): analysis of efficacy and correlation with HER2 and epidermal growth factor receptor expression in locally advanced or metastatic NSCLC. Journal of Clinical Oncology. 2003;21(14):2658-2663. [pmid: 12860941].
81 Cortas T, Eisenberg R, Fu P, et al. Activation state (phosphorylated) EGFR and STAT3 as prognostic markers in resected non-small cell lung cancer (NSCLC). 2005 ASCO Annual Meetings. 2005. Abstract #7090.
82 Lynch TJ, Bell DW, Sordella R, et al. Activating mutations in the epidermal growth factor receptor underlying responsiveness of non-small-cell lung cancer to gefitinib. New England Journal of Medicine. 2004;350(21):2129-2139. [pmid: 15118073].
83 Pao W, Miller V, Zakowski M, et al. EGF receptor gene mutations are common in lung cancers from"never smokers" and are associated with sensitivity of tumors to gefitinib and erlotinib. Proc Natl Acad Sci U S A. 2004;101(36):13306-13311. [pmid: 15329413].
84 Paez JG, Janne PA, Lee JC, et al. EGFR mutations in lung cancer: correlation with clinical response to gefitinib therapy. Science. 2004;304:1497-1450. [pmid: 15118125].
85 Huang SF, Liu HP, Li LH, et al. High frequency of epidermal growth factor receptor mutations with complex patterns in non-small cell lung cancers related to gefitinib responsiveness in Taiwan. Clinical Cancer Research. 2004;10(24):8195-8203. [pmid: 15623594].
86 Tokumo M, Toyooka S, Kiura K, et al. The relationship between epidermal growth factor receptor mutations and clinicopathologic features in non-small cell lung cancers. Clinical Cancer Research. 2005;11(3):1167-1173. [pmid: 15709185].
87 Cortes-Funes H, Almanza C, Valero P, et al. Epidermal growth factor receptor (EGFR)-activating mutations (mut) and response to gefitinib in lung adenocarcinoma. Journal of Clinical Oncology. 2005;23(16s). Abstract #7076.
88 Fujiwara Y, Kiura K, Toyooka S, et al. Effect of epidermal growth factor receptor gene mutations on adverse events of gefitinib in patients with non-small cell lung cancer. 2005 ASCO Annual Meetings. 2005. Abstract #7096.
89 Han SW, Jeong S, Choi IS, et al. EGFR and K-ras mutations as determinants of gefitinib sensitivity in non-small-cell lung cancer (NSCLC). 2005 ASCO Annual Meetings. 2005. Abstract #7078.
90 Kawada I, Soejima K, Watanabe H, et al. Quick screening of EGFR mutation using restriction fraction length polymorphism. 2005 ASCO Annual Meetings. 2005. Abstract #7071.
91 Kris MG, Sandler A, Miller VA, et al. EGFR and KRAS mutations in patients with bronchioloalveolar carcinoma treated with erlotinib in a phase II multicenter trial. 2005 ASCO Annual Meetings. 2005. Abstract #7029.
92 Lynch TJ, Bell D, Haber D, et al. Correlation of molecular markers including mutations with clinical outcomes in advanced non small cell lung cancer (NSCLC) patients (pts) treated with gefitinib, chemotherapy or chemotherapy and gefitinib in IDEAL and INTACT clinical trials. 2005 ASCO Annual Meetings. 2005. Abstract #7006.
93 Tsai C, Chiu C, Chou T, et al. Mutation in the tyrosine kinase domain of epidermal growth factor receptor is a predictive and prognostic factor for gefitinib treatment in patients with non-small cell lung cancer. 2005 ASCO Annual Meetings. 2005. Abstract #7086.
94 Hirsch FR, Gandara DR, McCoy J, et al. Increased EGFR gene copy number detected by FISH is associated with increased sensitivity to gefitinib in patients with bronchioloalveolar carcinoma (BAC) (S0126). 2005 ASCO Annual Meetings. 2005. Abstract #7030.
95 Fujiwara K, Kiura K, Gemba K, et al. Gefitinib ('Iressa', ZD1839) may restore chemosensitivity in NSCLC patients?. Anticancer Research. 2005;25(1B):547-549. [pmid: 15816627].