# SIX KEY QUESTIONS

Based on an assembly of valid evidence:

1. How confident are you that there is sufficient valid evidence to determine if non-invasive technologies can detect obstructive coronary artery lesions?
  - Which non-invasive technologies have sufficient valid evidence to undertake such a determination?
2. How confident are you that there is sufficient valid evidence to determine if these non-invasive technologies can accurately assess the anatomic location of obstructive coronary artery lesions?
  - Which non-invasive technologies have sufficient valid evidence to undertake such a determination?
3. How confident are you that there is sufficient valid evidence to determine if these non-invasive technologies can accurately assess the relevant morphology (size, shape, ulceration, etc) of obstructive coronary artery lesions?
  - Which non-invasive technologies have sufficient valid evidence to undertake such a determination?
4. How confident are you that non-invasive imaging can be used instead of coronary artery catheterization to determine treatment of coronary artery disease? If you are confident or very confident, in which populations should non-invasive imaging be used?
5. If non-invasive imaging were to be used in addition to coronary artery catheterization:
  - How confident are you that non-invasive imaging provides an incremental benefit or harm when used before coronary artery catheterization?
  - How confident are you that non-invasive imaging provides an incremental benefit or harm when used after coronary artery catheterization?
6. How confident are you that:
  a. The diagnostic test characteristics of the test are generalizable to the Medicare beneficiary population; and
  b. Diagnostic and treatment strategies using non-invasive imaging of coronary artery disease provide a net health benefit to Medicare beneficiaries compared to strategies that use invasive imaging?