# RESULTS

## General observations

Based on our literature search, we identified 30 studies using 16-array or greater MDCT assessing coronary CTA for evaluation of native coronary artery stenosis and 13 MRA studies evaluating native coronary artery stenosis using more recent MRI imaging sequences. (Evidence Table, see Appendix)

The vast majority of CTA studies were performed on 16-MDCT scanners, with 6 studies using 64-MDCT scanners for CTA. To provide a clearer picture of the most recent and thus most relevant literature, Table 1 lists only the 64-array MDCT studies along with the 5 prospective 16-array MDCT studies that enrolled at least 100 patients. This table includes major characteristics reflecting study quality and relevance to the key questions. The 16-array MDCT studies demonstrate the general limitations of the CT technology in assessing coronary artery stenosis. Higher reported sensitivities and specificities resulted when patient enrollment was limited to individuals who were in sinus rhythm and able to breath hold for 20–25 seconds (this latter requirement was often tested prior to enrollment in the study).17, 18 Additionally, coronary artery segments were excluded that were judged to be of poor image quality. In the largest consecutive prospective 16-array MDCT study with 149 patients in which all segments were analyzed, 23% of coronary segments were found to be poor quality.19

Additionally, 34% of the segments had notable coronary calcium and motion artifacts that limited evaluation in 24% of the patients. This study reported a sensitivity of 30% and a specificity of 91% when analyzed by coronary segments, and a sensitivity of 86% and a specificity of 49% when analyzed on a per patient basis.

Table 1 Larger Prospective 16-array MDCT CTA and 64-array CTA

Article # | N= | Mean Age | Population Consecutive Y or N(no or not stated) | Prospective (Y) or Retrospective (R) or Not Stated (N) | Blinded read (Y) or N (no or not stated | Imaging Technology Scanner Type (CT16, CT64, MRA) | Image Reconstruction Vendor (V) and/or (S) Standardized or N (Not Stated) | % Images non-diagnostic or N (Not stated) | Gold Standard and % receiving X-Ray Angio (A) | Analysis method: Patient (P) Vessel (V) segment (S) or Both (B) | Reported Sensitivity | Reported Spec. | Reported Harm: Radiation (R), Nephrotoxicity (K), (O) Other or Not Stated (N) | Comment
Burgstahler C 2005^20^ | 117 | 72 and 57 | Y | R | Y | CT16 (Siemens) | N | 6-B10% of segments not visualized, 11–18% stented or severe calcification, 17% only able to tell if presence or absence of vessel occlusion | A-100% | S | 80–89% (eval seg) | 96–98% (eval seg) | N | Two groups with mean age of 72 vs 57. Calcium score higher in older age cohort. Sensitivity decreased with age, but no sign difference in specificity. 3 patients overall excluded from lower age group due to technical problems with scan
Hoffmann MHK, 2005^17^ | 103 | 61.5 | Y | Y | Y | CT-16 (Phillips) | S | 6.4% segments 27% patients with only partial coronary tree coverage | A – 100% | B | 95% (segs) 97% (pts) | 98% (segs) 87% (all pts) | R – 8.3 mSv ave | Pts sinus rhythm able to breath hold 25 secs stent segs excluded
Mollet NR, 2004^18^ | 128 | 58.9 | N | Y | Y | CT16 (Siemens) | S | 1 pt excluded and stented segs excluded | A – 100% | B | 92% (segs) 100% (pt) | 95% (segs) 86% (pt) | N | Only vessels > 2 mm, sinus rhythm, pts can hold breath 20sec prior to enrollment, 60% beta-blocker, stented segs excluded
Kaiser C, 2005^19^ | 149 | 63.9 | Y | Y | Y | CT16 (Siemens) | N | 23% segments poor quality | A – 100% | S | 30% (all segs) 86% (all pts) | 91% (all segs) 49% (all pts) | N | Large study – analysis in all segs and pts, 34% segs with Calcium, motion artifacts 24% pts
Kuettner A, 2005^21^ | 124 | 64.1 | Y | Y | Y | CT16 (Siemens) | S | 4 patients excluded, 19% poor image quality | A – 100% | S | 85% (per patient) | 98% (per patient) | N | All segments, analysis only by patient, but for distal vessel segments did not perform well
Leschka S, 2005^22^ | 67 | 60.1 | Y | N | Y | CT64 (Siemens) | S | No segs excluded | A – 100% | B | 94% (all segs) | 97% (all segs) | N | Sinus rhythm, > 1.5 mm vessels
Fine JJ, 2006^23^ | 66 | 62 | Y | N | Y | CT64 (Siemens) | N | No exclusions, vessel only analysis | A – 100% | V | 95% (by vessel) | 96% (by vessel) | N | > 1.5 mm vessels,
Raff GL, 2005^24^ | 70 | 59 | Y | Y | Y | CT64 (Siemens) | N | 12% segs not evaluable | A – 100% | B | 86% (eval segs) 95% (eval pts) | 95% (eval segs) 90% (eval pts) | N | All segments including < 1.5 mm vessels, 26% with Ca+ agaston > 400, BMI>30 reduced accuracy
Leber AW, 2005^25^ | 59 | 64 | Y | Y | Y | CT64 (Siemens) | V | 4/59 (7%) patients non-evaluable images | A – 100% | B | 73% (eval segs) | 97% (eval segs) | N | Entire tree seen in 55 of 59 patients and used for analysis
Mollet NR, 2005^26^ | 51 | 59.6 | Y | Y | Y | CT64 (Siemens) | S | I patient scan not evaluable | A – 100% | B | 99% (eval segs) 100% (eval pt. | 95% (eval segs) 92%(eval pts) | N | 75% of patients with disease, multivessel in 45% patients, Ca+ agaston >400 in 18 pts
Ropers D, 2006^27^ | 84 | 58 | N | N | Y | CT64 (Siemens) | V | 4% patients and segs non-eval. | A – 100% | B | 93% (eval seg) 96% (eval pt) | 97% (eval seg) 91% (eval pt) | R Ave. 7.45 mSv men and 10.24 mSv women | > 1.5 mm vessels only

The 64-array MDCT studies overall have more consistent diagnostic image quality with higher reported sensitivity and specificity in the detection of coronary artery stenosis. Compared to 16-MDCT technology, scan time is faster for the 64-MDCT scanners and while spatial resolution is unchanged, temporal resolution may be improved. The representative study by Raff et al.24 was conducted with 70 patients with all vessels, including vessels <1.5 mm in diameter, analyzed. This study found 12% of segments were unevaluable. An Agatston calcium score >400 was observed in 26% of patients. In this subset, sensitivity appeared preserved (93% versus 94%) for patients with a calcium score <100, but specificity was reduced (67% versus 95%) for patients with calcium scores >100.

The majority of the coronary MRA studies were often unable to visualize the entire coronary tree or even the full extent of the major vessels. These studies often report the length of the major coronaries visualized, indicating incomplete coverage. In one prospective multi-center study of 109 patients evaluating MRA for coronary artery stenosis,28 16% of coronary segments were excluded due to poor image quality. Although the findings in evaluable segments were encouraging (sensitivity 100% and specificity of 85%), this study along with the other studies reviewed for this project demonstrate that there are still significant limitations of this technique in evaluating the entire coronary tree. By inference, these limitations constitute a barrier to the routine use of these tests in the clinical management of patients.

### Question 1 How confident are you that there is sufficient valid evidence to determine if non-invasive technologies can detect obstructive coronary artery lesions?

The Evidence Table provides an appendix of studies that met the inclusion criteria, and Table 1 presents the studies highlighted for discussion. Only five studies of coronary CTA used 16-array MDCT and prospectively enrolled more than 100 patients (Table 1). Six additional studies have evaluated CTA with a 64-array MDCT. All of these were single center and examined fewer than 100 patients. Disease detection was defined as >50% stenosis. Analysis by coronary segment produced sensitivity estimates ranging from 30% to 99% and specificity estimates ranging from 91 to 98%. For patient level analysis, reported sensitivity ranged from 85% to 100% and specificity ranged from 49% to 98%. Limitations include exclusion of segments of the coronary arteries and some of the studies report only analysis of evaluable segments or patients, not both.

MRA evaluation of obstructive coronary artery lesions is limited to the proximal and mid coronaries at this time, with a significant number of coronary segments or patients excluded from the analysis. The meta-analysis of Schuijf and colleagues published earlier this year identified 28 studies with a total of 980 patients.29 Operating characteristic estimates by coronary segment level analysis varied widely. Only four of the 28 studies included more than 50 subjects and only one enrolled consecutive subjects. We reviewed 12 studies with more recent technology (see Evidence Table).

The largest was a prospective multi-center study with 109 patients.28 Analysis was only reported by segment, with 16% of segments excluded due to technical problems. Sensitivity for evaluable segments was 100% with specificity of 85%. In the Schuijf meta-analysis, sensitivity overall in the 28 studies was 72% but fell to 58% when non-evaluable segments were included. Specificity was 87% but fell to 70% when non-evaluable segments were included.

### Question 2 How confident are you that there is sufficient valid evidence to determine if these non-invasive technologies can accurately assess the anatomic location of obstructive coronary artery lesions?

The anatomic location of coronary stenosis significantly affects the ability of NITs to detect and assess coronary stenosis and determine management plans. The available evidence suggests better performance with both CTA and MRA in assessment of more proximal portions of the coronary tree, particularly the left main coronary artery and the proximal segments of the left anterior descending (LAD), left circumflex (LCX), and right coronary artery (RCA). As with question 1, the reported results in the studies we reviewed were biased by exclusion of coronary segments due to inadequate image quality.

### Question 3 How confident are you that there is sufficient valid evidence to determine if these non-invasive technologies can accurately assess the relevant morphology (size, shape, ulceration, etc) of obstructive coronary artery lesions?

There are very limited data evaluating NIT’s ability to assess coronary artery lesion morphology. We identified five studies30–34 comparing NITs with intravascular ultrasound (IVUS) for coronary morphology. These studies included less than 50 patients and typically involved IVUS examinations of only one coronary artery. In these reports, NITs were able to identify some of the characteristics of plaque morphology such as calcification and plaque area.33 However, comparisons were largely made in segments without significant obstructive lesions. In addition, no attempt was made to link the angiographic findings to clinical outcomes.

### Question 4 How confident are you that non-invasive imaging can be used instead of coronary artery catheterization to determine treatment of coronary artery disease?

### Question 5 If non-invasive imaging were to be used in addition to coronary artery catheterization, how confident are you that it provides incremental benefit or harm when used a) before catheterization, and b) after catheterization?

The responses to questions 4 and 5 are combined as in both cases there are no direct data to support the substitution of the newer non-invasive coronary imaging techniques for invasive catheterization in order to select treatment for patients with suspected or known CAD, or use of such tests as an adjunct to x-ray angiography. The answer to this question at present can only be inferred using the limited evidence available on questions 1–3 along with some assumptions based on past experience with older diagnostic technologies. However, such an inference is not straightforward, and cannot be made on the basis of general principles of test use. The optimal decision depends on the complex relationship between pre-test probability of disease, test operating characteristics, and expected benefits and harms of various plausible management options. For example, test sensitivity and specificity estimates derived from high pre-test probability patients cannot be applied to low pre-test probability patients without adequate validation. The reason for this lies in the different operating characteristics of tests when applied to different stages/severity levels of a disease (in this case, CAD). Low pre-test probability populations not only have fewer patients with clinically significant disease, but also the cases of disease in this population are typically less advanced than in a high pre-test probability population.35

In the absence of direct evidence, decision models can be used to provide preliminary insights into the potential harms and benefits of different imaging technologies and strategies. While we did not identify such a published study of NITs for coronary anatomy, the model developed by Garber et al.36 provides some general insights about the potential impact of NITs as an alternative to initial x-ray angiography. This work provides two observations relevant to the current report. First, there was a very narrow range of quality-adjusted life years (QALY) across all strategies. The difference between the strategy with the highest QALY (catheterization alone) and the lowest was only 0.025 QALY for men and 0.028 QALY for women. Second, cost effectiveness did not vary much by age (only ages 45, 55 and 65 years were examined) but was sensitive to the severity of CAD. Older patients, who have more CAD and more severe CAD in particular, had more favorable incremental cost effectiveness ratios than younger ones.

A more recent, but currently unpublished, model developed by Dr. Gillian Sanders and colleagues at the Duke Clinical Research Institute and Stanford includes CT angiography as a testing strategy.37 This model, which was funded by Blue Cross Blue Shield (BCBS) Technology Evaluation Center, analyzes the effectiveness and cost effectiveness of non-invasive CTA compared with existing non-invasive tests (including exercise electrocardiography, single-photon emission tomography, and echocardiography) or immediate x-ray angiography. Analyses performed using this decision model demonstrate that, given a pre-test probability of 50% prevalence of coronary disease, in each age and gender group studied, proceeding directly to x-ray angiography produced the greatest quality-adjusted life expectancy while also being the most expensive testing strategy. Similarly, for all ages and genders, exercise electrocardiography was the least costly and least effective. The incremental quality-adjusted life expectancy benefit of angiography compared to exercise electrocardiography ranged from a low of 6.4 days in 45-year old women, to 18.3 days in 65-year old men. CTA had the highest quality-adjusted life expectancy of the non-invasive tests studied and the analysis suggested potential value (in terms of incremental cost effectiveness) of CTA as an alternative to other non-invasive tests and immediate x-ray angiography in select groups of symptomatic patients. Immediate x-ray angiography, although more effective than CTA, only increased quality-adjusted life expectancy by a low of 0.22 days in 45-year old women, to a high of 2.63 days in 65-year old men with an incremental cost effectiveness compared with CTA ranging from $133,400/QALY to $2,202,200/QALY. Notably, for the context evaluated with the model – individuals with a 50% pre-test probability of CAD, and accepting a plausible range of test operating characteristics from the literature as accurate and appropriate – CTA was not projected to provide a better net health outcome (in terms of QALYs) than immediate x-ray angiography.

### Question 6a How confident are you that the diagnostic test characteristics of the test are generalizable to the Medicare beneficiary population

Only two studies listed in Table 1 have a mean age of 65 or greater. Thus, the data on test performance in the Medicare aged population remains quite limited. Only one of the studies provided an explicit subgroup analysis by age.20 As the presence of calcium is associated with aging, as expected that for patients over the age of 65, when coronary artery disease is more prevalent and coronary artery calcium is more prevalent and severe, the operating characteristics of the test may change. Raff et al.24 noted sensitivity and specificity of 77% and 98% for individual segments when no calcium was noted in the coronary arteries and 93% and 72%, respectively, when severe calcium was present. Mollet26 also noted a drop in specificity with increasing coronary artery calcium. Burgstahler et al.20 demonstrate that in an older aged patient cohort (mean age 72 years vs 57 years) the sensitivity for detecting coronary artery stenosis was reduced from 89 to 80% with minimal change in specificity (96% vs 98%). It should be noted that in this study the calcium Agaston scores were not significantly different among the two populations. Stratification of data related to age, clinical pre-test probability of disease, and coronary artery calcium in multicenter large cohort group studies would give added strength to improve confidence of generalization of this technique to the Medicare patient population.

### Question 6b How confident are you that diagnostic and treatment strategies using non-invasive imaging of coronary artery strategies provide a net health benefit to Medicare beneficiaries?

There are no empirical data that examine this question directly. Just as with our response to questions 4 and 5, the answer to this question at present can only be inferred using the limited evidence available on questions 1–3. Assessing the net benefit will require data on the relative risks and benefits of the NITs in a Medicare population. Unfortunately, there are no data on the beneficial effects of the NITs on clinical decision making and subsequent clinical outcomes. Risks that should be considered in such studies should include direct risks at time of non-invasive coronary evaluation (including metallic risk, risk of contrast and radiation) and the downstream effects of poor test performance, such as unwarranted tests or missed diagnosis.