# METHODS

## Overview

The six key questions which form the focus of this report examine the degree to which the available scientific evidence allows a confident assessment of specific clinically relevant questions. They fall into two general categories: test accuracy/performance (questions 1, 2, 3 and 6a) and clinical impact (questions 4, 5, and 6b).

## Literature Review

### Identification of the Literature

We performed a literature search of non-invasive coronary imaging tests using two strategies. First, we reviewed the search strategies used and the indexing terms of articles found in three recent systematic reviews of coronary CT and/or MRI.1–3 We then devised an overall strategy to update those searches to the present using the MeSH headings Coronary Angiography AND (coronary disease or coronary stenosis) AND (tomography, x-ray computed or tomography, spiral computed or magnetic resonance imaging or magnetic resonance angiography) to search for articles published through the year 2005, limiting our search to articles published in English. Studies published prior to 2005 were identified from the three recent systematic reviews on this topic, which together included 92 studies, the vast majority of which were published before 2005. Our updated search resulted in 114 English language articles, 16 of which were previously identified in one or more of the recent reviews.

Second, we searched for review articles published since the year 2002 up to and including through 2005 that included the following text words in title, abstract, or subject headings: non-invasive, coronary, and imaging. This resulted in 123 English language articles. These reviews did not provide additional source articles related to the key questions, but served as a screen to identify possible technologies on the horizon.

The clinical inclusion criterion for articles was assessment of native coronary arteries. Subsequently, we excluded all articles that did not address native coronary artery stenosis.

### Assessment of the literature

Articles were reviewed with regard to the following characteristics:

- Volume of patients evaluated
- Prospective assessment of consecutive patients
- Standardized image acquisition and reconstruction
- Blinded interpretation
- Information provided about images of coronary segments/arteries that were deemed low quality or were otherwise uninterpretable
- Comparison with a gold standard
- Ability to identify CAD on a patient level and on a segment/vessel level
- Inclusion of subjects representative of Medicare beneficiaries.

For studies of clinical utility, we assessed whether the clinical context was clear, generalizability, and whether the outcomes assessed were clinically relevant.

Because of the preliminary nature of the available data for non-invasive coronary imaging, a full critical appraisal, including an independent confirmation of the correctness of reported test parameters such as sensitivity and specificity, is not warranted at this time. In many studies, some tested patients had some or all of their results omitted from the reported operating characteristics due to technical or other problems. Such omissions bias the reported operating characteristics upward.