# FUTURE RESEARCH

NIT imaging may be particularly attractive for individuals in whom invasive catheterization holds an exceptionally high risk for complications. This would include patients who have a higher risk of an embolic stroke due to extensive vascular disease in the aorta or endocarditis involving the aortic valve or those who are at high risk for development of a pseudoaneurysm at the site of catheter insertion due to underlying vascular disease. Additionally, potentially, any clinical indication for coronary angiography may be able to be evaluated with NIT, although data to evaluate individual clinical indications will be required.38

A variety of management strategies can be envisioned in which NIT imaging serves a gatekeeper role for the use of invasive catheterization. In this situation, invasive angiography will largely serve as a prelude to percutaneous revascularization. NIT imaging would generally not be used after invasive x-ray angiography since, at present, there is no evidence that the NIT provides incremental information.

In order to make a confident assessment of the clinical role of NITs in coronary artery disease, it will be crucial to assess test performance (sensitivity and specificity) with high quality studies in appropriate clinical contexts that extend beyond small, primarily single-center, proof-of-concept studies. In addition to establishing high test operating characteristics, it is essential to evaluate the utility of NITs in representative clinical settings. While it may be reasonable to assume that good operating characteristics will translate into improved clinical outcomes, this is not necessarily the case. For NITs in coronary artery disease, use of an NIT may have unintended consequences; at the individual level these may result from false positives or negatives, and at the population level these may relate to undesirable changes in practice patterns such as relatively indiscriminate testing in low risk settings.

There are three primary types of evidence that could address the question of substitution of non-invasive for invasive imaging: a randomized trial, an observational study (“natural experiment”), or a decision model.

A randomized trial could take several forms and could use either surrogate or patient-related outcomes. For example, patients with suspected CAD could be randomized to a strategy of “usual diagnostic evaluation,” including invasive angiography when indicated, or usual diagnostic evaluation plus option for non-invasive coronary imaging. Alternatively, the patients could be randomized between early invasive and early non-invasive coronary imaging. Outcomes could include hard events such as death or MI, as well as efficiency measures including resource consumption and costs.

A “natural experiment” observational study would examine apparently similar patients referred for alternative diagnostic strategies, including early invasive, early non-invasive coronary imaging, and stress imaging. The notion of a “natural experiment” assumes that there is an element of randomness in clinical practice that can be exploited analytically. If the use of a technology in the practice community has matured to the point where there is significant confounding with patient characteristics, even advanced statistical adjustment techniques may not suffice to uncover unconfounded outcomes.

A decision model would examine the most likely diagnostic strategies of interest along with predicted health outcomes and resource use. Since there is a high level of dependency of test performance and treatment benefit and harm on clinical context, such considerations would likely require separate models. Further, sensitivity analyses to identify effects on decision thresholds are a central part of such an exercise.