# DISCUSSION

There is limited evidence regarding test performance of NITs for identifying, quantifying, or otherwise characterizing coronary artery stenoses (Key Questions 1, 2, 3, and 6a). Specifically, there is a paucity of prospective studies evaluating NITs in a blinded fashion against the gold standard, x-ray angiography. While there has been reported variability in the quality of the gold standard10, it is nevertheless accepted in clinical practice as the imaging study to diagnose and manage coronary artery stenosis. The available evidence allows some preliminary judgments on the ability of coronary MRA (1.5 T) and coronary CTA using at least 16-array MDCT technology to detect obstructive coronary artery lesion in the proximal to mid coronary arteries. The evidence regarding detection of coronary lesions in branch vessels or distal coronary arteries remains unclear. There is no direct evidence regarding the clinical utility of NITs in terms of the incremental benefits or risks relative to alternative testing strategies (Key Questions 4, 5, and 6b). Indirect evidence based on modeling studies is also limited; existing analyses suggest that individuals with mid range pretest probability of CAD do not have a net benefit from CTA, but non-invasive testing can lead to more rational application of resources by influencing the use of further tests and treatments.