# CONTEXT OF THIS REPORT

The Centers for Medicare and Medicaid Services (CMS), through the Agency for Healthcare Research and Quality (AHRQ), have commissioned the Duke Center for Clinical Health Policy Research Evidence-based Practice Center (EPC) to perform an evaluation of the available scientific evidence on direct non-invasive imaging tests (NITs) for coronary artery disease relative to coronary angiography. Our report is focused around six key questions provided to us by AHRQ and CMS. The objective of this report is to provide background information to the Medicare Coverage Advisory Committee (MCAC) in their review of these six questions (see below) during their May 2006 meeting.

The six key questions examine the degree to which current evidence supports confident judgments about the use of NITs in the assessment of coronary anatomy in clinical practice. The specific focus of this report is computed tomographic angiography (CTA) and magnetic resonance angiography (MRA) for evaluating native coronary arteries. In addition, the MCAC is interested in technologies on the horizon, as well as the general issue of establishing the value of NITs in specific clinical contexts in which coronary disease is being considered.