# BACKGROUND

## Introductory concepts and assessment of coronary artery anatomy

Atherosclerotic cardiovascular disease remains the primary cause of mortality and morbidity among adults in the United States. Coronary artery disease (CAD) refers to that portion of the spectrum of atherosclerotic disease in which significant amounts of atherosclerotic plaque builds up in the epicardial coronary arteries, reducing downstream blood flow to the heart muscle. CAD is a progressive process characterized by periods of apparent quiescence interspersed with active, sometimes life-threatening, manifestations of disease. The major clinical manifestations include angina pectoris, acute coronary syndromes (including both unstable angina and acute myocardial infarction), congestive heart failure, malignant ventricular arrhythmias, and sudden cardiac death. Unfortunately, the disease does not progress in a predictable fashion from less severe to more severe symptoms. Thus, the first evidence of coronary atherosclerosis may be a sudden cardiac death or a myocardial infarction causing permanent impairment of heart function.

For this reason, the appropriate diagnostic evaluation of patients who may have CAD is of considerable practical importance. Too little testing may fail to identify the disease at a stage when medical intervention can still save life or prevent disability. Too much testing can lead to unnecessary therapies, to incidental findings that may induce additional testing with the attendant risks involved, to avoidable anxieties for the patient, and to wasteful use of scarce health care resources. Although a full discussion of this subject is considerably beyond the scope of this report, a few general concepts will be introduced as background to what follows.

A “diagnostic test” can be used to examine either diagnostic questions (e.g., does this patient have significant coronary artery disease?) or prognostic questions (e.g., what are the chances that this patient will die or have a heart attack in the next year?). Diagnostic questions are much more frequently represented in the medical literature because the studies are easier to perform. However, prognostic questions are ultimately more closely aligned with the concerns of the patient and the physician. The difficulty of performing prognostic studies lies in the large samples and extended periods (i.e., years) of follow-up required. All the studies reviewed in this report fall into the former category of studies addressing diagnostic questions.

The performance of diagnostic tests is typically judged against a reference standard (often termed the “gold standard”). In the case of the non-invasive tests considered in this report, that standard is invasive coronary angiography. Test performance is typically evaluated in terms of test “operating characteristics.” The operating characteristics measure how well the new non-invasive tests correctly identify patients with disease (sensitivity or the proportion of patients with disease who have a “positive” non-invasive test) and patients without disease (specificity or the proportion of patients without disease who have a “negative” test). The ideal non-invasive test would have both a very high sensitivity and a very high specificity. In practice, however, there is typically a trade off between sensitivity and specificity such that only one can be maximized at a time.

The measurement of test operating characteristics is not a simple matter. Substantial biases can be introduced into the measurements by choice of the subjects to be studied. The ideal population is comprised of individuals for whom there is true diagnostic uncertainty and for whom the test in question would have the potential to influence management. However, most published studies of test operating characteristics select study subjects for convenience rather than relevance. Thus, inclusion of normal subjects without suspected CAD symptoms to define test specificity provides a biased assessment of specificity.4 Similarly, inclusion of patients with known CAD (based, for example, on prior coronary angiography or prior myocardial infarction) will usually bias sensitivity upwards. These spectrum biases can result in substantially misleading estimates of test performance. Characteristically, overoptimistic measures of test performance appear early in the life cycle of a new test, only to be supplanted gradually over a period of years by more realistic performance statistics.5, 6

Diagnostic tests for CAD, whether addressing diagnostic or prognostic questions, do not by themselves alter outcome unless there is a complication during test performance. To have an impact on outcomes, test results must influence subsequent management for better, or perhaps, for worse. Thus, the test must be interpreted, placed into clinical context for each individual patient. In the case of CAD, the general treatment options are medical therapy and revascularization. Medical therapy is focused on two objectives: symptom relief and improvement of prognosis. For example, nitroglycerin can reduce the symptoms of angina, while aspirin does not affect symptoms but can reduce the chances that a CAD patient will die or have a heart attack. Some therapies, such as beta blockers can accomplish both objectives. Revascularization can be accomplished either with coronary artery bypass graft surgery (CABG) or percutaneous coronary intervention (PCI). The latter includes both balloon angioplasty and coronary stenting. The decision about whether to initiate medical therapy for CAD and whether to add revascularization to medical therapy depends on the details of the clinical presentation including medical history, physical examination, and initial diagnostic tests. Once the physician has made an initial assessment, they may choose to start therapy, perform additional non-invasive tests, or refer for invasive angiography. The evaluation of what revascularization procedure a patient is eligible for is based heavily on a detailed assessment of the invasive coronary angiogram.

Since invasive angiography is not itself a therapy, it only provides benefit to the patient if it can lead to a change (improvement) in management. Depending on the population considered, a substantial segment of the more than one million diagnostic angiographies performed in the US each year do not lead to revascularization. The impetus behind the development of improved non-invasive diagnostic strategies for CAD is to allow confident identification of patients who do not need (or who are not candidates for) revascularization, thus sparing them an invasive procedure while still being able to identify that segment of the CAD population who will derive either prognostic or symptomatic benefit from revascularization.

The basic goal of the new direct non-invasive imaging studies for CAD is to be able to provide an anatomic evaluation of the epicardial coronary arteries without the risks of an invasive procedure. The technical challenges are considerable. The coronary arteries lie on the outer surface of the heart in a complex three-dimensional pattern that differs from one individual to the next. In addition, the coronary arteries are small, with internal dimensions from about 1 mm to over 4 mm, and the heart is in almost continual motion. Modern invasive coronary angiography has excellent spatial (approximately 0.2 mm) and temporal (50 milliseconds) resolution. The technical challenge in supplanting invasive angiography has been to develop new techniques that can approximate in quality what clinicians have been accustomed to using in making treatment decisions.

Much of the available literature on the new NITs addresses the question of whether non-invasive imaging has achieved this objective as a technical matter.

One of the main criticisms of treatment decision making based only on coronary angiography is that such an approach does not take account of the fact that a coronary lesion may appear “significantly” obstructive, but may not affect downstream myocardial performance and vice versa. To assess the “functional” importance of coronary disease, clinicians often use non-invasive tests such as exercise/stress echocardiography, exercise/stress single proton emission computed tomography (SPECT), myocardial perfusion imaging, and, more recently, stress magnetic resonance (MR) perfusion imaging. These tests evaluate the coronary circulation at rest and again during exercise or pharmacological stress either by looking at patterns of blood flow into the heart muscle (perfusion studies) or at the contraction patterns of the left ventricle. Comparison of the rest and exercise/stress images helps identify areas of reversible reduction in blood flow (i.e., ischemia) as well as areas of prior heart attack. A significant reduction in blood flow to a section of the heart muscle supplied by a narrowed coronary artery will show up during exercise or stress as an area of reduced uptake of perfusion imaging agent on SPECT imaging or as abnormal wall motion (contraction) on echocardiography. A heart attack causes irreversible damage to the heart muscle leading to an area of scarring, which does not have blood flow and does not contract.

Current practice involves many permutations in the use of tests to diagnose CAD. In the elective setting, patients may be referred initially for a stress test and only referred to invasive angiography if the stress test is sufficiently abnormal. In some cases, the clinician may start with a treadmill electrocardiogram (ECG) stress test. If the result is judged ambiguous (i.e., neither clearly positive nor clearly negative), the second test selected may be a stress imaging study, such as nuclear SPECT perfusion study or a stress echo, both of which have increased accuracy for diagnosis of CAD relative to stress ECG testing. In the acute setting, patients are often referred for early angiography as the initial risk stratification test although lower risk patients may be evaluated first with non-invasive testing. After cardiac catheterization, some patients may be referred for non-invasive stress testing to define the “functional significance” of a coronary stenosis that is borderline in severity, or is located in such a way as to increase the risk of treatment with percutaneous revascularization. Some cardiovascular experts advocate for a diagnostic strategy that includes both anatomy information (from direct coronary imaging) and functional information collected during exercise or pharmacological stress. There is no current gold standard test that achieves both of these objectives. The future evolution of non-invasive diagnostic strategies may seek not only to supplant some fraction of currently performed invasive angiographies, but also to provide a more comprehensive data base for clinical decision making that includes non-invasive data on both coronary anatomy and functional response of the coronary circulation to exercise/stress.

## Technologies for imaging coronary artery anatomy

### X-ray Angiography

Traditionally, coronary anatomy has been defined by x-ray angiography. This technique involves introducing a catheter into the femoral, brachial, or radial artery; passing that catheter up the aorta; and directly engaging the right and left coronary arteries and injecting an iodinated contrast agent into each while making digital x-ray images. Significant improvements in technique and equipment have been introduced over the past 20 years that have reduced the risks of the procedure to patients.7, 8 These risks for diagnostic coronary angiography include arterial bleeding from the access site, embolization of atherosclerotic material causing stroke or heart attack due to catheter manipulation in the aorta and coronary arteries, anaphylaxis or renal injury from the contrast agent used to visualize the coronary arteries on x-ray images, and radiation exposure. The direct mortality risk from diagnostic cardiac catheterization is estimated to be 0.1%.9 The limitations of invasive x-ray angiography as a gold standard for coronary artery disease including variability and the ability to only identify luminal obstruction are well known.10, 11 However, x-ray angiography remains the routine standard for clinical care.

To avoid exposing patients to the risk of an unnecessary invasive angiography, diagnostic strategies have been developed using non-invasive myocardial imaging techniques. These techniques, which include echocardiography and myocardial nuclear perfusion scanning, do not provide direct visualization of coronary artery anatomy. Rather, they evaluate myocardial wall motion or perfusion at rest and under stress and any abnormal findings are used to make inferences about the presence and severity of obstructive coronary artery disease and the resulting need for invasive coronary artery imaging. It is beyond the scope of the present review to more than note that these non-invasive cardiac tests have wide variability in reported sensitivities and specificities.12 It is in this context that the NITs are being introduced.

### CTA and MRA

Two non-invasive technologies to directly image coronary artery anatomy are available in the United States and are in active development: computed tomography angiography (CTA) and magnetic resonance angiography (MRA). For the purpose of this report it is particularly notable that neither of these imaging modalities has yet reached technological maturity. Ongoing research is particularly focused on the special challenges of coronary anatomy imaging: the need for excellent spatial resolution (to image very small vessels from 4 mm to <1.5mm in size) and superb temporal resolution (to image very quickly to reduce artifact from cardiac and respiratory motion).

Coronary artery CTA involves intravenous injection of an iodinated contrast agent followed by rapid imaging (over 10 to 15 seconds) of the heart with a multi-detector row computed tomography (MDCT) scanner. With increasing number of detectors (16, 40, 64) and faster tube rotation, MDCT scanners are now able to acquire images from the whole heart which result in fewer artifacts from both cardiac and respiratory motion. Risks involved in using this technique include radiation exposure (quantified at 3–4 times the radiation exposure for diagnostic invasive angiography)13 and the use of iodinated contrast, which can be nephrotoxic for certain patients.

MRA of the coronaries can be performed with or without the administration of a gadolinium-based intravenous contrast agent during ECG gated magnetic resonance imaging of the heart. MRA techniques for coronary artery assessment have included both 2-dimensional and 3-dimensional image acquisition along the imaging plane of the coronary artery with different methods for motion artifact reduction (either breath hold or free breathing “navigator” sequences). Patients with severe claustrophobia or with certain metallic foreign bodies or implanted devices may not be suitable for this type of non-invasive imaging. This technique does not involve radiation exposure and the contrast agent, at the dose used for MRA, is not considered nephrotoxic. MRA sequences still require either breath hold of 16–30 seconds or free breathing with sequence calibration to respiratory motion. Respiratory motion artifact remains a significant concern for MRA imaging of the coronary arteries. Initial investigations are now being conducted with the use of 3 Tesla MRI scanners (most MR scanners in current use are 1.5 Tesla) to image coronary arteries and the hope is that the superior signal to noise ratio of these new machines will allow improved imaging of the coronary circulation.

The potential for imaging artifacts and incorrect interpretation exists for both coronary CTA and MRA studies. Both modalities require image acquisition paired to cardiac motion so as to isolate imaging during a period of relatively limited cardiac motion (diastole) to decrease motion artifact, which is a blurring or ghosting of the image that can result in a poor-quality or unusable image. Reduction of motion artifact requires that image acquisition be timed to heart rhythm and rate, a process known as ECG-gating. Therefore, patients with either irregular heart rhythms, such as frequent premature atrial or ventricular contractions, or atrial fibrillation may have significant artifacts when tested with CTA or MRA. Pre-test administration of beta-blockers is routinely used to slow heart rates since faster heart rates decrease the time spent in diastole when the heart is (momentarily) at rest. Respiratory motion also presents imaging problems, some of which have been diminished by short (<20 second) imaging times with MDCT.

The presence of coronary calcium (a component of complex atherosclerotic plaques) also can present significant potential interpretation difficulty for CTA as coronary stenosis underlying coronary calcium may be obscured by x-ray beam hardening artifacts depending on the degree of calcification of the vessel or degree of stenosis may be overestimated.14 For coronary MRA, overcoming respiratory motion, results in long examination times. In contrast to coronary CTA, calcium results as an area of signal void and may result in overestimation of stenosis. These above artifacts are not routinely seen on traditional x-ray angiography due to its superior temporal and spatial resolution.

In addition to patient-related testing issues, the methodology and technology used in image reconstruction can also affect the accuracy of image interpretation and alter a test’s clinical utility. Both CTA and MRA require complex post-processing reconstruction of images. At present, there is no agreed standard method for these computer-based reconstructions, which tend to be proprietary and vary by manufacturer.

### Electron Beam Computed Tomography

Electron beam computed tomography (EBCT) technology is an imaging technology that uses electrocardiogram (ECG) gating and high-speed cine CT scanning to generate cross sectional images of the heart. EBCT has been used most successfully to quantitate calcium deposits in the coronary arteries. Coronary calcium has been correlated with overall atherosclerotic burden and with the risk of future myocardial infarction and death.1–3 To date, this technology has not achieved the level of resolution required to image coronary artery anatomy and stenosis well. Further, its role in clinical screening for CAD remains controversial.15, 16 Consequently, it is not considered further in this report.

### Combined Direct and Indirect NITs

While the focus of this report is on technologies for directly assessing coronary artery anatomy, work is ongoing to improve indirect tests of coronary artery disease, as well. These include research into contrast agents for perfusion echocardiography, radionuclide agents for both SPECT and PET imaging, and stress cardiovascular magnetic resonance evaluating both wall motion and myocardial perfusion. Because of the limitations of these technologies when used individually, there is particular interest in the potential for combining non-invasive myocardial imaging techniques with direct non-invasive coronary imaging. Examples of promising combinations include the use of PET with CTA or perfusion MRI with MRA angiography. These may provide a more complete evaluation of the epicardial coronary arteries and myocardial function and perfusion in a single setting.