# (EVIDENCE TABLE)

Evidence Table

Article # | N= | Age mean | Population Consecutive Y or N(no or not stated) | Prospective (Y) or Retrospective (R) or Not Stated (N) | Blinded read (Y) or N (no or not stated | Imaging Technology Scanner Type (CT16, CT64, MRA)^*^ | Image Reconstruction Vendor (V) and/or (S) Standardized or N (Not Stated) | % Images non-diagnostic or N (Not stated) | Gold Standard and % receiving X-Ray Angio (A) | Analysis method: Patient (P) Vessel (V) segment (S) or Both (B) | Reported Sensitivity | Reported Spec. | Reported Harm: Radiation (R), Nephrotoxicity (K), (O) Other or Not Stated (N) | Comment:
Achenbach S, 2005^39^ | 50 | 62 | Y | Y | Y | CT16 (Siemens) | N | 2 patients excluded 4% segs | A – 100% | B | 94% (eval segs) 100% (eval pts) | 96% (eval segs) 83% (eval pts) | N | > 1.5 mm vessel only, 128 distal segments excluded prior to analysis
Aviram G, 2005^40^ | 22 | 57 | Y | N | Y | CT16 (Phillips) | S | All segs included | A – 100% | S | 86% (all segs) | 98% (all segs) | Did include info on anomalous vessel course | 14 of 22 patients had CAD, only vessels > 1.5 mm
Bogaert J, 2003^41^ | 21 | 62 | N | Y | Y | MRA – 1.5T (Phillips) | V | 2 patients 29% segs excluded | A – 100% | V | 55.5% (eval segs) | 83.7% (eval segs) | N | Limited number of visible segments, navigator – free breathing
Burgstahler C, 2005^20^ | 117 | 72 and 57 | Y | R | Y | CT16 (Siemens) | N | 6-B10% of segments not visualized, 11–18% stented or severe calcification, 17% only able to tell if presence or absence of vessel occlusion | A-100% | S | 80–89% (eval seg) | 96–98% (eval seg) | N | Two groups with mean age of 72 vs 57. Calcium score higher in older age cohort. Sensitivity decreased with age, but no sign difference in specificity. 3 patients overall excluded from lower age group due to technical problems with scan.
Cademartiri F, 2005^42^ | 126 | 59 | N | R | Y | CT16 (Siemens) | N | Not clear, only > 2 mm segs | A – 100% | B | 90% (low Ca) 92% (high Ca) | 97% (low Ca) 91% (high Ca) | R – estimated 8 mSv men 13 mSv women | Only > 2 mm segs, cut group into 60 low Ca,60 high Ca without accuracy difference
Cury RC, 2005^43^ | 29 | 58 | Y | N | Y | CT16 (Siemens) | S | 16% of known stenosis from Angio excluded on MDCT | A – 100% | S | Not reports – linear comparison to angio QCA | Not reports – linear comparison to angio QCA | R – do mention dose modulation and reduction in radiation | Evaluation of MDCT to QCA on angio from minor to significant stenosis. 16% known stenosis excluded for calcium/motion artifact
Fine JJ, 2004^44^ | 50 | 58 | Y | Y | Y | CT16 (Siemens)^*^ | N | 2% segments | A – 100% | V | 87% (eval segs) | 97% (eval segs) | N | Vessels > 1.5 mm only
Fine JJ, 2006^23^ | 66 | 62 | Y | N | Y | CT64 (Siemens) | N | No exclusions, vessel only analysis | A – 100% | V | 95% (by vessel) | 96% (by vessel) | N | > 1.5 mm vessels,
Ghersin E, 2006^45^ | 66 | 57 | Y | Y | Y | CT16 (Phillips) | V | 11% pts then 20% segs non-eval | A – 100% | S | 80% (eval segs) | 89% (eval segs) | N | No beta-blockers, acute chest pain patients, 60% with AMI, prior stents in population
Gulati GS, 2005^46^ | 31 | 53 | N | R | Y | CT16 (Siemens)^*^ | V | 14% segments non-eval. | A – 100% | S | 85% (eval seg) | 94% (eval seg) | N | > 1.5 mm vessels only, 5 patients with coronary anomalies
Heuschmid M, 2005^47^ | 37 | 56 | N | N | Y | CT16 (Siemens)^*^ | S | 22.1% of segs non-eval | A – 100% | B | 59% (eval segs) | 87% (eval seg) | N | Sensitivity rose to 93% in patients with lower Ca score (<1000)
Hoffmann U, 2004^14^ | 33 | 57 | Y | Y | Y | CT16 (Siemens) | S | 17% with restricted quality | A – 100% | B | 63% (segs) | 96% (segs) | N | Calcification accounted for 94% of False +
Hoffmann MHK, 2005^17^ | 103 | 61.5 | Y | Y | Y | CT-16 (Phillips) | S | 6.4% segments 27% patients with only partial coronary tree coverage | A – 100% | B | 95% (segs) 97% (pts) | 98% (segs) 87% (all pts) | R – 8.3 mSv ave | Pts sinus rhythm able to breath hold 25 secs; stent segs excluded
Ikonen AEJ, 2003^48^ | 69 | 58 | N | N | Y | MRA – 1.5T (Siemens) | N | 16% segs excluded | A – 100% | V | 75% (eval segs) | 62% (eval segs) | N
Kaiser C, 2005^19^ | 149 | 63.9 | Y | Y | Y | CT16 (Siemens) | N | 23% segments poor quality | A – 100% | S | 30% (all segs) 86% (all pts) | 91% (all segs) 49% (all pts) | N | Large study – analysis in all segs and pts, 34% segs with Calcium, motion artifacts 24% pts
Kefer J, 2005^49^ | 56 | 65 | N | Y | Y | CT16 (Phillips) and MRA 1.5T (Phillips) | S | 6 patients (10%) did not undergo all three tests | A – 100% | B | 75% MRA 82% MDCT | 77% MRA 79% MDCT | N | Study evaluating both MDCT and MRA to angiogram all in same patients.
Kim WY, 2001^28^ | 109 | 59 | Y | Y | Y | MRA – 1.5T (Phillips) | N | 16% segs excluded | A – 100% | V | 100% (eval segs) | 85% (eval segs) | | Prospective, Multicenter, free-breathing, LM and prox-mid coronaries only
Kuettner A, 2004^50^ | 60 | 58 | Y | Y | Y | CT16 (Siemens)^*^ | S,V | 21% poor image quality | A – 100% | B | 72% (all segs) | 97% (all segs) | N | Accuracy goes up as high calcium patients excluded
Kuettner A, 2005^51^ | 72 | 64 | Y | N | Y | CT16 (Siemens) | N | 6.6% segs | A – 100% | B | 82% (segs) | 98% (segs) | N | Mean calcium mass 86
Kuettner A, 2005^21^ | 124 | 64.1 | Y | Y | Y | CT16 (Siemens) | S | 4 patients excluded, 19% poor image quality | A – 100% | S | 85% (per patient) | 98% (per patient) | N | All segments, analysis only by patient, but for distal vessel segments did not perform well
Leber AW, 2005^25^ | 59 | 64 | Y | Y | Y | CT64 (Siemens) | V | 4/59 (7%) patients non-evaluable images | A – 100% | B | 73% (eval segs) | 97% (eval segs) | N | Entire tree seen in 55 of 59 patients and used for analysis
Leschka S, 2005^22^ | 67 | 60.1 | Y | N | Y | CT64 (Siemens) | S | No segs excluded | A – 100% | B | 94% (all segs) | 97% (all segs) | N | Sinus rhythm, > 1.5 mm vessels
Manning WJ, 1993^52^ | 39 | 54 | N – only when MRA available | Y | Y | MRA – 1.5T (Siemens) | N | 7 vessels excluded | A – 100% | V | 90% (eval vessels) | 92% (eval vessels) | N | MRI contraindications, two Left coronary systems not evaluated due to time constraints
Martuscelli E, 2004^53^ | 64 | 58 | N | N | Y | CT16 (GE) | N | 16% segs 3 pts excluded | A – 100% | B | 89% (evaluable segs) 78% (all segs) | 98% (evaluable segs) Not reports all segs | N | All patients B-Blocker, only vessesl >1.5 mm included, 3 pts excluded 1 - HR.70, 2-breath hold
Mollet NR, 2004^18^ | 128 | 58.9 | N | Y | Y | CT16 (Siemens) | S | 1 pt excluded and stented segs excluded | A – 100% | B | 92% (segs) 100% (pt) | 95% (segs) 86% (pt) | N | Only vessels > 2 mm, sinus rhythm, pts can hold breath 20sec prior to enrollment, 60% beta-blocker, stented segs excluded
Mollet NR, 2005^54^ | 51 | 58.9 | N | Y | Y | CT16 (Siemens) | N | All evaluated | A – 100% | B | 95% (segs) 100% (pt) | 98 (segs) 85% (pt) | N | Only vessels > 2 mm, sinus rhythm, pts can hold breath 20sec prior to enrollment
Mollet NR, 2005^26^ | 51 | 59.6 | Y | Y | Y | CT64 (Siemens) | S | I patient scan not evaluable | A – 100% | B | 99% (eval segs) 100% (eval pt. | 95% (eval segs) 92%(eval pts) | N | 75% of patients with disease, multivessel in 45% patients, Ca+ agaston >400 in 18 pts
Moon J-Y, 2005^55^ | 61 | 59.3 | N | Y | Y | CT16 (Siemens)^*^ | N | 3 pts (5%) not evaluable | A – 100% | B | 85.7% (eval - pts) 80.6% (eval – segs) | 91.3% (eval-pts) 93.4% (eval-segs) | N | All got B-Blocker, only Vessels > 2.0 mm,
Morgan-Hughes GJ, 2005^56^ | 58 | 61 | Y | Y | Y | CT16 (GE) | S,V | 1 pt excluded | A – 100% | S | 83% (all segs) | 97% (all segs) | N
Muller MF, 1997^57^ | 35 | 61 | N | Y | Y | MRA – 1.5T (Siemens) | S | 5 pts excluded (14%) | A – 100% | S | 83% (eval pts) | 94% (eval pts) | N
Muller MF, 2004^58^ | 30 | 60 | N | N | Y (but not blinded to PTCA location) | MRA – 1.5T (Siemens) | N | 15% poor image quality | A – 100% | S | 82% (all segs) | 85% (all segs) | N | LM and coronaries in 3 segments (prox,mid,dis), all pts with previous PTCA
Nieman K, 2002^59^ | 59 | 58 | N | N | Y | CT16 (Siemens)^*^ | N | Only looked at main vessel and 2 mm sidebranches | A – 100% | V | 95% (vess) | 86% (vess) | N | 34 patients given additional B-blocker
Raff GL, 2005^24^ | 70 | 59 | Y | Y | Y | CT64 (Siemens) | N | 12% segs not evaluable | A – 100% | B | 86% (eval segs) 95% (eval pts) | 95% (eval segs) 90% (eval pts) | N | All segments including < 1.5 mm vessels, 26% with Ca+ agaston > 400, BMI>30 reduced accuracy
Regenfus M, 2000^60^ | 50 | 60.7 | N | N | Y | MRA – 1.5T (Siemens) | V | 24.4% segs excluded | A – 100% | P and V | 94.4% (eval.pts) | 57.1% (eval pts) | N | Only 82% of patients could breath hold for 32-heartbeat sequence
Ropers D, 2003^61^ | 77 | 58 | Y | N | N | CT16 (Siemens)^*^ | S | 12% segs all arteries evaluable in 74% pts | A – 100% | B | 85% (pt) | 78% (pt) | N | All got B-Blocker, only Vessels > 1.5 mm,
Ropers D, 2006^27^ | 84 | 58 | N | N | Y | CT64 (Siemens) | V | 4% patients and segs non-eval. | A – 100% | B | 93% (eval seg) 96% (eval pt) | 97% (eval seg) 91% (eval pt) | R Ave. 7.45 mSv men and 10.24 mSv women | > 1.5 mm vessels only
Sakuma H, 2005^62^ | 39 | 63.9 | N | N | N | MRA – 1.5T (Phillips) | S | 13% patients non-eval | A – 51% | V | 82% (eval pts getting angio) | 91% (eval pts getting angio) | N | Only 51% of patients got gold standard angiogram
Sandstede JJ, 1999^63^ | 30 | NA | N | N | Y | MRA – 1.5T (Siemens) | N | 23% pts excluded | A – 100% | V | 81% (eval pts) | 89% (eval pts) | N | Navigator sequence, vessel analysis, no branches, not clear total # excluded
Schuijf JD, 2005^64^ | 45 | 63 | N | N | Y | CT16 (Toshiba) | S | 6% of segs | A – 100% | S | 85% (eval-segs) | 89% (eval-segs) | N | Study includes grafts and stents along with native coronaries
So NM, 2005^65^ | 29 | 60.2 | N | Y | Y | MRA – 1.5T (Siemens) | N | 19% segs non-eval | A – 100% | V,P | 92.8% (eval pt) | 95.3% (eval pt) | N
Van Geuns RJ, 2000^66^ | 38 | (43–72) | N | N | Y | MRA – 1.5T (Siemens) | V | 31% segs excluded 4 patients excluded | A – 100% | V | 68% (eval pts) | 97% (eval pts) | N | Only proximal and mid coronary sections included
Watanabe Y, 2002^67^ | 12 | NA | N | N | Y | MRA – 1.5T (Phillips) | S,V | 30% segs poor quality | A – 100% | V | 96% (eval segs/pts) | 88% (eval seg/pts) | N | Navigator, large number of segs excluded, vessel analysis
Wittlinger T, 2002^68^ | 25 | 62.2 | N | N | Y | MRA – 1.5T (Siemens) | N | 5 pts (20%) excluded then 15% segs poor quality | A – 100% | V | 75% (eval segs/pts) | 100% (eval segs/pts) | N | Only prox/mid vessel assessment

* =Used a 16 MDCT with a 12×0.75 configuration.