# EXECUTIVE SUMMARY

This report describes an evaluation of the available scientific evidence on direct non-invasive imaging tests (NITs) for coronary artery disease. In particular, we focus on six key questions provided by the Agency for Healthcare Research and Quality (AHRQ) and the Centers for Medicare and Medicaid Services (CMS). The objective of this report is to provide background information to the Medicare Coverage Advisory Committee (MCAC) in their review of these questions during their May 2006 meeting. The six key questions examine the degree to which current evidence supports confident judgments about the use of NITs in the assessment of coronary anatomy in clinical practice. The two NITs that are examined in detail in this report are computed tomographic angiography (CTA) and magnetic resonance angiography (MRA) for evaluating native coronary arteries. In addition, we consider technologies on the horizon, as well as the general issue of establishing the value of NITs in specific clinical contexts in which coronary disease is being considered.

## Methods

We performed a literature search of non-invasive coronary imaging tests using two strategies. First, we reviewed the search strategies used and the indexing terms of articles found in three recent systematic reviews of coronary CT and/or MRI.1–3 We then devised an overall strategy to update those searches to the present using the MeSH headings Coronary Angiography AND (coronary disease or coronary stenosis) AND (tomography, x-ray computed or tomography, spiral computed or magnetic resonance imaging or magnetic resonance angiography) to search for articles published through the year 2005, limiting our search to articles published in English. Studies published prior to 2005 were identified from the three recent systematic reviews on this topic, which together included 92 studies, the vast majority of which were published before 2005. Our updated search resulted in 114 English language articles, 16 of which were previously identified in one or more of the recent reviews. Second, we searched for review articles published since the year 2002 up to and including through 2005 that included the following text words in title, abstract, or subject headings: non-invasive, coronary, and imaging. This resulted in 123 English language articles. Subsequently, we excluded all articles that did not address native coronary artery stenosis.

Articles were reviewed with regard to characteristics likely to influence the validity of the results and their applicability to individuals likely to be Medicare beneficiaries. For studies of clinical utility, we assessed whether the clinical context was clear and generalizable, and whether the outcomes assessed were clinically relevant.

## Results

We identified 29 studies using 16-array or greater multi-detector computed tomography (MDCT) assessing coronary CTA for evaluation of native coronary arteries stenosis, and 13 MRA studies evaluating native coronary artery stenosis using more recent MRI imaging sequences. These studies were generally small, performed at single centers, and often did not include information that would serve to provide confident assessments of the key questions. In particular, we did not identify any studies evaluating the clinical impact of diagnostic strategies including NITs of coronary anatomy compared with strategies that did not include these techniques. The populations studied tended to be relatively young (<65 years of age), and limited results subgrouped by age were available. Future approaches to non-invasive imaging of the coronary arteries will consist of technical improvements to CTA and MRA, as well as combinations of these modalities with non-invasive studies of myocardial function at rest and during stress.

## Conclusions

At present, there is limited evidence regarding test performance of NITs for identifying, quantifying, or otherwise characterizing coronary artery stenoses. The available evidence provides preliminary data on the ability of coronary MRA (1.5 T) and coronary CTA using at least 16-array MDCT technology to detect obstructive coronary artery lesion in the proximal to mid coronary arteries. The evidence regarding detection of coronary lesions in branch vessels or distal coronary arteries remains unclear and may well improve as the technology improves. Studies conducted to date primarily fall into the “proof of concept” category with study patients having a high pre-test probability of CAD. Patients providing suboptimal images were often excluded from calculations of test accuracy. Future work will need to examine these tests in larger, less selected populations representing the clinical settings in which they are actually expected to be used.