# REFERENCES

1 Arad Y, Goodman KJ, Roth M, et al. Coronary calcification, coronary disease risk factors, C-reactive protein, and atherosclerotic cardiovascular disease events: the St. Francis Heart Study.[see comment]. J Am Coll Cardiol. 2005;46(1):158-165. [pmid: 15992651].
2 Keelan PC, Bielak LF, Ashai K, et al. Long-term prognostic value of coronary calcification detected by electron-beam computed tomography in patients undergoing coronary angiography. Circulation. 2001;104(4):412-417. [pmid: 11468202].
3 Shaw LJ, Raggi P, Schisterman E, et al. Prognostic value of cardiac risk factors and coronary artery calcium screening for all-cause mortality. Radiology. 2003;228(3):826-833. [pmid: 12869688].
4 Rozanski A, Diamond GA, Forrester JS, et al. Alternative referent standards for cardiac normality. Implications for diagnostic testing. Ann Intern Med. 1984;101(2):164-171. [pmid: 6742646].
5 Rozanski A, Diamond GA, Berman D, et al. The declining specificity of exercise radionuclide ventriculography. N Engl J Med. 1983;309(9):518-522. [pmid: 6877322].
6 Thornbury JR, Fryback DG. Technology assessment--an American view. Eur J Radiol. 1992;14(2):147-156. [pmid: 1563415].
7 Johnson LW, Lozner EC, Johnson S, et al. Coronary arteriography 1984–1987: a report of the Registry of the Society for Cardiac Angiography and Interventions. I. Results and complications. Catheter Cardiovasc Diag. 1989;17(1):5-10.
8 Pohler E, Gunther H, Diekmann M, et al. Outpatient coronary angiography--safety and feasibility. Cardiology. 1994;84(4–5):305-309. [pmid: 8187117].
9 Lozner EC, Johnson LW, Johnson S, et al. Coronary arteriography 1984–1987: a report of the Registry of the Society for Cardiac Angiography and Interventions. II. An analysis of 218 deaths related to coronary arteriography. Catheter Cardiovasc Diag. 1989;17(1):11-14.
10 Leape LL, Park RE, Bashore TM, et al. Effect of variability in the interpretation of coronary angiograms on the appropriateness of use of coronary revascularization procedures. Am Heart J. 2000;139(1 Pt 1):106-113. [pmid: 10618570].
11 Topol EJ, Nissen SE. Our preoccupation with coronary luminology. The dissociation between clinical and angiographic findings in ischemic heart disease.[see comment]. Circulation. 1995;92(8):2333-2342. [pmid: 7554219].
12 Lee TH, Boucher CA. Clinical practice. Noninvasive tests in patients with stable coronary artery disease.[see comment]. N Engl J Med. 2001;344(24):1840-1845. [pmid: 11407346].
13 Hunold P, Vogt FM, Schmermund A, et al. Radiation exposure during cardiac CT: effective doses at multi-detector row CT and electron-beam CT. Radiology. 2003;226(1):145-152. [pmid: 12511683].
14 Hoffmann U, Moselewski F, Cury RC, et al. Predictive value of 16-slice multidetector spiral computed tomography to detect significant obstructive coronary artery disease in patients at high risk for coronary artery disease: patient-versus segment-based analysis. Circulation. 2004;110(17):2638-2643. [pmid: 15492297].
15 Chen J, Krumholz HM. How useful is computed tomography for screening for coronary artery disease? Screening for coronary artery disease with electron-beam computed tomography is not useful.[comment]. Circulation. 2006;113(1):125-146. discussion 125-46. [pmid: 16400723].
16 Clouse ME. How useful is computed tomography for screening for coronary artery disease? Noninvasive screening for coronary artery disease with computed tomography is useful.[see comment]. Circulation. 2006;113(1):125-146. discussion 125-46. [pmid: 16391167].
17 Hoffmann MHK, Shi H, Schmitz BL, et al. Noninvasive coronary angiography with multislice computed tomography.[see comment][erratum appears in JAMA. 2005 Sep 14;294(10):1208]. JAMA. 2005;293(20):2471-2478. [pmid: 15914747].
18 Mollet NR, Cademartiri F, Nieman K, et al. Multislice spiral computed tomography coronary angiography in patients with stable angina pectoris. J Am Coll Cardiol. 2004;43(12):2265-2270. [pmid: 15193691].
19 Kaiser C, Bremerich J, Haller S, et al. Limited diagnostic yield of non-invasive coronary angiography by 16-slice multi-detector spiral computed tomography in routine patients referred for evaluation of coronary artery disease.[see comment]. Eur Heart J. 2005;26(19):1987-1992. [pmid: 15972287].
20 Burgstahler C, Beck T, Kuettner A, et al. Image quality and diagnostic accuracy of 16-slice multidetector spiral computed tomography for the detection of coronary artery disease in elderly patients. J Comput Assist Tomogr. 2005;29(6):734-738. [pmid: 16272841].
21 Kuettner A, Beck T, Drosch T, et al. Image quality and diagnostic accuracy of non-invasive coronary imaging with 16 detector slice spiral computed tomography with 188 ms temporal resolution. Heart. 2005;91(7):938-941. [pmid: 15958366].
22 Leschka S, Alkadhi H, Plass A, et al. Accuracy of MSCT coronary angiography with 64-slice technology: first experience.[see comment]. Eur Heart J. 2005;26(15):1482-1487. [pmid: 15840624].
23 Fine JJ, Hopkins CB, Ruff N, et al. Comparison of accuracy of 64-slice cardiovascular computed tomography with coronary angiography in patients with suspected coronary artery disease. Am J Cardiol. 2006;97(2):173-174. [pmid: 16442357].
24 Raff GL, Gallagher MJ, O'Neill WW, et al. Diagnostic accuracy of noninvasive coronary angiography using 64-slice spiral computed tomography. J Am Coll Cardiol. 2005;46(3):552-557. [pmid: 16053973].
25 Leber AW, Knez A, von Ziegler F, et al. Quantification of obstructive and nonobstructive coronary lesions by 64-slice computed tomography: a comparative study with quantitative coronary angiography and intravascular ultrasound.[see comment]. J Am Coll Cardiol. 2005;46(1):147-154. [pmid: 15992649].
26 Mollet NR, Cademartiri F, van Mieghem CAG, et al. High-resolution spiral computed tomography coronary angiography in patients referred for diagnostic conventional coronary angiography.[see comment]. Circulation. 2005;112(15):2318-2323. [pmid: 16203914].
27 Ropers D, Rixe J, Anders K, et al. Usefulness of multidetector row computed tomography with 64×0.6 mm collimation and 330-ms rotation for the noninvasive detection of significant coronary artery stenoses. Am J Cardiol. 2006;97(3):343-348. [pmid: 16442393].
28 Kim WY, Danias PG, Stuber M, et al. Coronary magnetic resonance angiography for the detection of coronary stenoses.[see comment]. N Engl J Med. 2001;345(26):1863-1869. [pmid: 11756576].
29 Schuijf JD, Bax JJ, Shaw LJ, et al. Meta-analysis of comparative diagnostic performance of magnetic resonance imaging and multislice computed tomography for noninvasive coronary angiography. Am Heart J. 2006;151(2):404-411. [pmid: 16442907].
30 Caussin C, Ohanessian A, Ghostine S, et al. Characterization of vulnerable nonstenotic plaque with 16-slice computed tomography compared with intravascular ultrasound. Am J Cardiol. 2004;94(1):99-104. [pmid: 15219516].
31 Leber AW, Knez A, Becker A, et al. Accuracy of multidetector spiral computed tomography in identifying and differentiating the composition of coronary atherosclerotic plaques: a comparative study with intracoronary ultrasound. J Am Coll Cardiol. 2004;43(7):1241-1247. [pmid: 15063437].
32 Moselewski F, Ropers D, Pohle K, et al. Comparison of measurement of cross-sectional coronary atherosclerotic plaque and vessel areas by 16-slice multidetector computed tomography versus intravascular ultrasound. Am J Cardiol. 2004;94(10):1294-1297. [pmid: 15541250].
33 Pohle K, Achenbach S, B M, et al. Characterization of non-calcified coronary atherosclerotic plaque by multi-detector row CT: Comparison to IVUS. Atherosclerosis. 2006. (in press).
34 Schoenhagen P, Tuzcu EM, Stillman AE, et al. Non-invasive assessment of plaque morphology and remodeling in mildly stenotic coronary segments: comparison of 16-slice computed tomography and intravascular ultrasound. Coron Artery Dis. 2003;14(6):459-462. [pmid: 12966267].
35 Hlatky MA, Pryor DB, Harrell FE Jr, et al. Factors affecting sensitivity and specificity of exercise electrocardiography. Multivariable analysis. Am J Med. 1984;77(1):64-71. [pmid: 6741986].
36 Garber AM, Solomon NA. Cost-effectiveness of alternative test strategies for the diagnosis of coronary artery disease.[see comment]. Ann Intern Med. 1999;130(9):719-728. [pmid: 10357690].
37 Sanders G. Orlando L, editor. Personal Communications. 2006.
38 Schoenhagen P, Stillman AE, Garcia MJ, et al. Coronary artery imaging with multidetector computed tomography: A call for an evidence-based, multidisciplinary approach. Am Heart J. 2006;151(5):945-948. [pmid: 16644309].
39 Achenbach S, Ropers D, Pohle F-K, et al. Detection of coronary artery stenoses using multi-detector CT with 16×0.75 collimation and 375 ms rotation.[see comment]. Eur Heart J. 2005;26(19):1978-1986. [pmid: 15923203].
40 Aviram G, Finkelstein A, Herz I, et al. Clinical value of 16-slice multi-detector CT compared to invasive coronary angiography. Int J Cardiovasc Intervent. 2005;7(1):21-28. [pmid: 16019611].
41 Bogaert J, Kuzo R, Dymarkowski S, et al. Coronary artery imaging with real-time navigator three-dimensional turbo-field-echo MR coronary angiography: initial experience. Radiology. 2003;226(3):707-716. [pmid: 12601209].
42 Cademartiri F, Mollet NR, Lemos PA, et al. Impact of coronary calcium score on diagnostic accuracy for the detection of significant coronary stenosis with multislice computed tomography angiography. Am J Cardiol. 2005;95(10):1225-1227. [pmid: 15877996].
43 Cury RC, Pomerantsev EV, Ferencik M, et al. Comparison of the degree of coronary stenoses by multidetector computed tomography versus by quantitative coronary angiography. Am J Cardiol. 2005;96(6):784-787. [pmid: 16169361].
44 Fine JJ, Hopkins CB, Hall PAX, et al. Noninvasive coronary angiography: agreement of multi-slice spiral computed tomography and selective catheter angiography. Int J Cardiovasc Imaging. 2004;20(6):549-552. [pmid: 15856641].
45 Ghersin E, Litmanovich D, Dragu R, et al. 16-MDCT coronary angiography versus invasive coronary angiography in acute chest pain syndrome: a blinded prospective study. AJR Am J Roentgenol. 2006;186(1):177-184. [pmid: 16357399].
46 Gulati GS, Seth S, Kurian S, et al. Non-invasive diagnosis of coronary artery disease with 16-slice computed tomography. Natl Med J India. 2005;18(5):236-241. [pmid: 16433135].
47 Heuschmid M, Kuettner A, Schroeder S, et al. ECG-gated 16-MDCT of the coronary arteries: assessment of image quality and accuracy in detecting stenoses. AJR Am J Roentgenol. 2005;184(5):1413-1419. [pmid: 15855088].
48 Ikonen AEJ, Manninen HI, Vainio P, et al. Three-dimensional respiratory-gated coronary MR angiography with reference to X-ray coronary angiography. Acta Radiol. 2003;44(6):583-589. [pmid: 14616201].
49 Kefer J, Coche E, Legros G, et al. Head-to-head comparison of three-dimensional navigator-gated magnetic resonance imaging and 16-slice computed tomography to detect coronary artery stenosis in patients. J Am Coll Cardiol. 2005;46(1):92-100. [pmid: 15992641].
50 Kuettner A, Trabold T, Schroeder S, et al. Noninvasive detection of coronary lesions using 16-detector multislice spiral computed tomography technology: initial clinical results.[see comment]. J Am Coll Cardiol. 2004;44(6):1230-1237. [pmid: 15364324].
51 Kuettner A, Kopp AF, Schroeder S, et al. Diagnostic accuracy of multidetector computed tomography coronary angiography in patients with angiographically proven coronary artery disease.[see comment]. J Am Coll Cardiol. 2004;43(5):831-839. [pmid: 14998625].
52 Manning WJ, Li W, Edelman RR. A preliminary report comparing magnetic resonance coronary angiography with conventional angiography.[see comment][erratum appears in N Engl J Med 1993 Jan 13;330(2):152]. N Eng J Med. 1993;328(12):828-832.
53 Martuscelli E, Romagnoli A, D'Eliseo A, et al. Accuracy of thin-slice computed tomography in the detection of coronary stenoses. Eur Heart J. 2004;25(12):1043-1048. [pmid: 15191775].
54 Mollet NR, Cademartiri F, Krestin GP, et al. Improved diagnostic accuracy with 16-row multi-slice computed tomography coronary angiography. J Am Coll Cardiol. 2005;45(1):128-132. [pmid: 15629386].
55 Moon J-Y, Chung N, Choi BW, et al. The utility of multi-detector row spiral CT for detection of coronary artery stenoses. Yonsei Med J. 2005;46(1):86-94. [pmid: 15744810].
56 Morgan-Hughes GJ, Roobottom CA, Owens PE, et al. Highly accurate coronary angiography with submillimetre, 16 slice computed tomography. Heart. 2005;91(3):308-313. [pmid: 15710708].
57 Muller MF, Fleisch M, Kroeker R, et al. Proximal coronary artery stenosis: three-dimensional MRI with fat saturation and navigator echo. J Magn Reson Imaging. 1997;7(4):644-651. [pmid: 9243382].
58 Muller MF, Fleisch M. Recurrent coronary artery stenosis: assessment with three-dimensional MR imaging. J Magn Reson Imaging. 2004;20(3):383-389. [pmid: 15332244].
59 Nieman K, Cademartiri F, Lemos PA, et al. Reliable noninvasive coronary angiography with fast submillimeter multislice spiral computed tomography.[see comment]. Circulation. 2002;106(16):2051-2054. [pmid: 12379572].
60 Regenfus M, Ropers D, Achenbach S, et al. Noninvasive detection of coronary artery stenosis using contrast-enhanced three-dimensional breath-hold magnetic resonance coronary angiography. J Am Coll Cardiol. 2000;36(1):44-50. [pmid: 10898411].
61 Ropers D, Baum U, Pohle K, et al. Detection of coronary artery stenoses with thin-slice multi-detector row spiral computed tomography and multiplanar reconstruction. Circulation. 2003;107(5):664-666. [pmid: 12578863].
62 Sakuma H, Ichikawa Y, Suzawa N, et al. Assessment of coronary arteries with total study time of less than 30 minutes by using whole-heart coronary MR angiography. Radiology. 2005;237(1):316-321. [pmid: 16126921].
63 Sandstede JJ, Pabst T, Beer M, et al. Three-dimensional MR coronary angiography using the navigator technique compared with conventional coronary angiography. AJR Am J Roentgenol. 1999;172(1):135-139. [pmid: 9888755].
64 Schuijf JD, Bax JJ, Salm LP, et al. Noninvasive coronary imaging and assessment of left ventricular function using 16-slice computed tomography. Am J Cardiol. 2005;95(5):571-574. [pmid: 15721093].
65 So NM, Lam WW, Li D, et al. Magnetic resonance angiography of coronary arteries with a 3-dimensional magnetization-prepared true fast imaging with steady-state precession sequence compared with conventional coronary angiography. Am Heart J. 2005;150(3):530-535. [pmid: 16169336].
66 van Geuns RJ, Wielopolski PA, de Bruin HG, et al. MR coronary angiography with breath-hold targeted volumes: preliminary clinical results. Radiology. 2000;217(1):270-277. [pmid: 11012456].
67 Watanabe Y, Nagayama M, Amoh Y, et al. High-resolution selective three-dimensional magnetic resonance coronary angiography with navigator-echo technique: segment-by-segment evaluation of coronary artery stenosis. J Magn Reson Imaging. 2002;16(3):238-245. [pmid: 12205578].
68 Wittlinger T, Voigtlander T, Rohr M, et al. Magnetic resonance imaging of coronary artery occlusions in the navigator technique.[see comment]. Int J Cardiovasc Imaging. 2002;18(3):203-211. discussion 213-5. [pmid: 12123312].