# Results

## Results of Literature Searches

The results of the literature search and study selection are summarized in the flow chart below (Figure 2). A total of 3,471 potentially relevant citations were identified, of which 3,310 came from database searches and 161 were added after reviewing the bibliographies of previous reports and relevant articles. After dual review of abstracts and titles, 3,368 articles were excluded (14 of which were identified from the updated literature search and were already included in the report). The remaining 103 articles underwent dual review at the full-text level and 46 studies (in 50 publications) met the inclusion criteria and were included in this report: 16 randomized controlled trials (RCTs), 13 comparative observational studies, and 17 case series.

For the comparison of radiofrequency ablation with medical therapy a total of 20 studies (23 publications) were included: 13 RCTs35–47 and 7 comparative observational studies.48–54 Also summarized under this comparison for Key Question 2 only were an additional 17 case-series, included specifically for information regarding the safety of catheter ablation.55–71 For the comparison of cryoablation with medical therapy, only one RCT (2 publications) was included.72, 73 For the comparison of ablation using different energy sources, a total of eight studies were included: two RCTs74, 75 and six comparative observational studies.76–81 A list of included studies can be found in Appendix B.

A total of 53 articles that did not meet one or more of the inclusion criteria were excluded after full-text review. Appendix C provides a list of these articles with reasons for exclusion. One, five, six, and four studies were excluded because they did not include populations, interventions, comparisons, and outcomes of interest, respectively. Ten studies were excluded because they were the wrong study design. Four examined investigational or non-US Food and Drug Administration (FDA)-approved devices (e.g., laser balloon ablation, phased RFA). The remainder were excluded for the following reasons: cases series with less than 1000 patients (n=8); comparative observational study with less than 100 patients (7 studies); same population as prior included study (6 studies); did not address any of the Key Questions (1 study); and duplicate publication (1 study).

Figure 2 Flow chart showing results of literature search*

Cryo = cryoablation; FDA = US Food and Drug Administration; KQ = Key Question; Med = medical therapy; RCT = randomized controlled trial; RFA = radiofrequency Ablation.

*This is a modified PRISMA flow diagram.27, 82

†Some RCTs have multiple publications.

‡All of the randomized trials, and 11 of the 13 comparative observational studies included in KQ1 and KQ3 also provided data for KQ2.

Figure 2. This figure is a flow chart that outlines study retrieval and selection process. It begins with the total number of citations retrieved from the literature searches and ends with the number of studies that satisfied the inclusion criteria of the report. This figure is described further in the Section entitled “Results of Literature Searches”. Briefly: “A total of 3,471 potentially relevant citations were identified, of which 3,310 came from database searches and 161 were added after reviewing the bibliographies of previous reports and relevant articles. After dual review of abstracts and titles, 3,368 articles were excluded (14 of which were identified from the updated literature search and were already included in the report). The remaining 103 articles underwent dual review at the full text level and 46 studies (in 50 publications) met the inclusion criteria and were included in this report: 16 randomized controlled trials, 13 comparative observational studies, and 17 case series.” Of the 53 studies excluded at full-text review, the majority were excluded for the following reasons: no population, intervention, comparison, or outcome of interest (16); wrong study design (10); and case series with less than 1000 patients (8); comparative observational study with less than 100 patients (7).

## Organization of Results

For each Key Question, key points were presented followed by detailed information from evidence synthesis for the following comparisons: radiofrequency ablation versus medical therapy, cryoablation versus medical therapy, and comparisons between ablation energy sources. All included studies that investigated cryoablation used a cryoballoon catheter; therefore, this intervention is referred to throughout as “cryoballoon ablation”. Results are presented overall if appropriate and then by atrial fibrillation (AF) type with the focus on the outcomes considered to be most clinically important as previously described. With regard to AF type, results are reported for paroxysmal AF, persistent AF and, for studies which did not separate results by AF type, these were termed mixed.

## Key Question 1a What is the comparative efficacy and effectiveness of AF catheter ablation versus medical therapy on short-term (6–12 months) and long-term (>12 months) outcomes in the general adult and Medicare populations?

### Key Points

#### Radiofrequency Ablation Versus Medical Therapy

No RCTs in Medicare patients were identified for any of the following key outcomes. Of the comparative observational studies, two included Medicare populations (patients ≥65 years of age). Overall, findings from the comparative observational studies were consistent with those reported by the RCTs unless otherwise noted below.

There was substantial crossover from medical treatment to radiofrequency (RFA) in most RCTs.

##### Primary Outcomes

###### All-Cause Mortality (>30 days)

- Short term (≤12 months):
  - Overall: All-cause mortality was rare across seven RCTs (RFA: 0%–3.8%; medical therapy: 0%–2.9%) (low strength of evidence). RFA does not appear to affect all-cause mortality, and no statistical difference between treatments was reported.
  - Paroxysmal AF: Based on data from three RCTs, RFA does not appear to affect all-cause mortality in patients with paroxysmal AF (RFA: 0%–1.0%; medical therapy: 0%–3.6%) (low strength of evidence).
  - Persistent AF: Based on data from three RCTs, RFA does not appear to affect all-cause mortality in patients with persistent AF (RFA: 0%–3.8%; medical therapy: 0%) (low strength of evidence).
  - Medicare subpopulation: No RCTs or comparative observational studies were available (insufficient strength of evidence)
- Long term (>12 months):
  - Paroxysmal AF: Based on data from two RCTs, RFA does not appear to affect all-cause mortality in patients with paroxysmal AF (RFA: 0%–1.4%; medical therapy: 0%–2.8%) (low strength of evidence).
  - Persistent AF: No data were reported for the general population (insufficient strength of evidence).
  - Medicare subpopulation: All-cause mortality was comparable between groups in one observational study in patients with persistent AF (RFA: 1.3%; medical therapy: 1.9%) but was greater in the medical therapy arm in another observational study (RFA: 2.1%; medical therapy: 16.5%) that included those with both paroxysmal and persistent AF (insufficient strength of evidence).

###### Stroke (>30 days)

- Short term (≤12 months):
  - Paroxysmal AF: No strokes were observed in either treatment group in one RCT (insufficient strength of evidence).
  - Persistent AF: No strokes were observed in either treatment group in one RCT (insufficient strength of evidence).
  - Medicare subpopulation: No evidence available (insufficient strength of evidence).
- Long term (>12 months):
  - Paroxysmal AF: No strokes were observed in either treatment group one RCT (insufficient evidence).
  - Persistent AF: No evidence available (insufficient strength of evidence).
  - Mixed: Four observational studies assessed stroke and consistently found greater stroke rates in the medical therapy groups (insufficient strength of evidence).
  - Medicare subpopulation: Comparable frequency of stroke or transient ischemic attack (TIA) in both groups (RFA: 1.3%; medical therapy: 1.9%) in those with persistent AF, but in a single study in a mixed population frequency of stroke was greater following medical therapy (RFA: 0%; medical therapy: 1.5 %) (insufficient strength of evidence).

###### Myocardial Infarction (>30 days)

- Short term (≤12 months):
  - Paroxysmal AF: Myocardial infarction (MI) was rare across two RCTs (RFA: 0%–1.0%; medical therapy: 0%–1.8%) (low strength of evidence). All MIs were fatal and included in the results for mortality.
  - Persistent AF: No data reported (insufficient strength of evidence).
  - Medicare subpopulation: No evidence available (insufficient strength of evidence)
- Long term (>12 month):
  - Paroxysmal AF: MI was rare in both treatment groups as reported by one RCT (insufficient strength of evidence).
  - Persistent AF: No evidence available (insufficient strength of evidence).
  - Medicare subpopulation: Comparable MI events in both groups (RFA: 0%; medical therapy: 0.4%) in those with persistent AF, but higher frequency of MI for the ablation group (RFA: 1.4%; medical therapy: 0%) in the mixed population (insufficient strength of evidence).

###### Congestive Heart Failure

- Short term (≤12 months): No data on congestive heart failure (CHF) was reported for the general population or Medicare subpopulation (insufficient strength of evidence).
- Long term (>12 months):
  - Paroxysmal AF: No difference between groups in risk of congestive heart failure (CHF) development by 24 months in one RCT (insufficient strength of evidence).
  - Persistent AF: No data reported (insufficient strength of evidence).
  - Mixed AF: Three observational studies demonstrated greater heart failure hospitalizations in with medical therapy as compared to RFA (insufficient strength of evidence).
  - Medicare subpopulation: CHF development was comparable between groups (RFA: 0%; medical therapy 1.2%) in those with persistent AF, in contrast to the significantly higher frequency in the medical treatment group in a study with a mixed population (RFA: 0.7%; medical therapy: 9.8%) (insufficient strength of evidence).

###### Health-Related Quality of Life

- A variety of health-related quality of life (HRQOL) measures were used at varied time frames across trials. This, combined with possible clinical heterogeneity across studies, limits the ability to draw firm conclusions. The Short-Form 36 (SF-36) was the most frequently used measure but was reported in a variety of ways across different time frames, which limited the ability to pool results. Overall, statistical differences between treatments were not consistently seen across HRQOL measures, time frames, or types of AF.
- Short term (≤12 months):
  - Paroxysmal AF: No differences in SF-36 Mental Component Scores (MCS) (pooled estimate for difference in change scores 1.88; 95% confidence interval [CI] −0.47 to 4.50) and SF-36 Physical Component Scores (PCS) (pooled estimate for difference in change scores 2.88; 95% CI −0.18 to 5.25) were seen in two RCTs (insufficient strength of evidence) or in EuroQOL five dimensions (EQ5D) or Symptom Checklist frequency scale scores in one RCT; however, in the latter RCT, a difference favoring RFA in the Symptom Frequency severity scale was reported (insufficient strength of evidence for EQ5D and the Symptom Checklist).
  - Persistent AF: No differences between treatment groups were seen in change from baseline for SF-36 MCS (1 RCT) or in the Atrial Fibrillation Quality of Life Questionnaire (AF-QOL) or Kansas City Cardiomyopathy (KCCQ) scores (1 RCT each); however, for the SF-36 PCS a greater change was observed for the RFA group in one RCT and one trial reported improved New York Heart Association (NYHA) Functional Classification scores for the RFA group (insufficient strength of evidence for all). Across three trials in patients with heart failure, two reported a difference favoring RFA at 6 months in the Minnesota Living with Heart Failure Questinnaire (MLHFQ) and while not statistically significant, a third tended to favor RFA (low strength of evidence). Only one trial reported that this persisted to 12 months (low strength of evidence).
  - Medicare subpopulation: No evidence available (insufficient strength of evidence).
- Long term (>12 months):
  - Paroxysmal AF: SF-36 MCS and PCS were similar between groups at 24 months (one RCT) and at 48 months (one RCT) (insufficient strength of evidence at both time frames).
  - Persistent AF: No RCTs reported HRQOL past 12 months (insufficient strength of evidence).
  - Medicare Subpopulation: No evidence available (insufficient strength of evidence).

##### Intermediate Outcomes

###### Freedom From Recurrence (>30 days)

- Short term (≤12 months):
  - Overall: Freedom from recurrence of any arrhythmia was greater for RFA versus medical therapy based on data from nine RCTs (pooled relative risk [RR] 2.62; 95% CI 1.90 to 3.96) (moderate strength of evidence).
  - Paroxysmal AF: Based on data from four RCTs, catheter ablation is superior to medical therapy at improving freedom from recurrence of any atrial arrhythmia (pooled RR 3.06; 95% CI 2.35 to 3.90) (moderate strength of evidence).
  - Persistent AF: Based on data from three RCTs, catheter ablation is superior to medical therapy at improving freedom from recurrence of any atrial arrhythmia (RFA: 58%–75%; medical therapy: 4%–58%) (low strength of evidence).
- Long term (>12 months):
  - Paroxysmal AF: Based on data from three RCTs, catheter ablation is superior to medical therapy at improving freedom from recurrence of any atrial arrhythmia (pooled RR 1.24; 95% CI 1.11 to 1.47) (moderate strength of evidence).
  - Persistent AF: No data reported (insufficient strength of evidence).

###### Maintenance of Sinus Rhythm

- Short term (≤12 months):
  - Paroxysmal AF: One RCT found that RFA is superior to medical therapy at improving maintenance of sinus rhythm while a second found no difference between groups (RFA: 88%–92%; medical therapy: 35.4%–87%) (low strength of evidence).
  - Persistent AF: Based on two RCTs of heart failure patients, catheter ablation is superior to medical therapy at improving maintenance of sinus rhythm (RFA: 50%–88%; medical therapy: 0%–7.7%) (low strength of evidence).
- Long term (>12 months): No data reported in the general population (insufficient strength of evidence).
  - Medicare subpopulation: In patients with persistent AF sinus rhythm was maintained in 58 percent of the RFA group versus 43 percent of the medical therapy group. (insufficient strength of evidence)

###### Reablation (>30 days)

- Short term (≤12 months):
  - Overall: The frequency of reablation following RFA varied across seven RCTs (range, 0%–43%) (low strength of evidence).
  - Paroxysmal AF: Based on data from three RCTs, the frequency of reablation following RFA ranged from 0 percent to 43 percent (low strength of evidence).
  - Persistent AF: The frequency of reablation following RFA varied across four RCTs (pooled risk 20.1%; 95% CI 11.0 to 34.1) (low strength of evidence).
- Long term (>12 months):
  - Paroxysmal AF: The frequency of reablation following RFA varied across four RCTs (pooled risk 24.2%; 95% CI 12.6 to 41.5) (low strength of evidence).
  - Persistent AF: No data reported (insufficient strength of evidence).
  - Medicare subpopulation: 18.3 percent of patients with persistent AF required reablation in a single observational study (insufficient strength of evidence)

#### Cryoablation Versus Medical Therapy

No RCTs or comparative observational studies in Medicare patients were identified for cryoballoon ablation or focal cryoablation versus medical therapy. One fair-quality RCT was identified comparing cryoballoon ablation which reported only short-term (≤12 months) outcomes in patients with paroxysmal or persistent AF. This study had substantial crossover from medical therapy to cryoballoon ablation.

##### Primary Outcomes

- In the cryoballoon ablation group, one death occurred, due to an MI at 10 months postprocedure (this event was counted as both all-cause mortality and MI, 0.6% for both); three strokes (1.8%) and no TIAs were reported; and one patient (0.6%) was hospitalized with AF-related CHF. None of these events occurred in the medical therapy group. For HRQOL, no comparative data were reported (insufficient strength of evidence for all outcomes).

##### Intermediate Outcomes

- Freedom from protocol-defined treatment failure was significantly greater in the cryoablation group (69.9%) compared with the group treated medically (7.3%) (low strength of evidence).

### Radiofrequency Ablation Versus Medical Therapy

#### Description of Included Studies

##### Randomized Controlled Trials

Thirteen RCTs compared RFA with medical therapy. Short-term outcomes were reported by 11 RCTs,36–41, 43–47 with followup past the blanking period of 12 months available in 10 and 13 months available in one trial.45 Three RCTs reported on long-term outcomes, with followup ranging from 24 to 48 months.35, 42, 83 One trial published 12 and 48 month outcomes in two separate articles.44, 83 The blanking period ranged from 1 to 3 months across 12 RCTs; one RCT43 did not report on the length of the blanking period. Six RCTs only included patients with paroxysmal AF,35, 38, 42, 44, 46, 47, 83 five only included patients with persistent AF,37, 39–41, 43 and two trials included patients with either paroxysmal or persistent AF (“mixed”);36, 45 study characteristics are presented in Tables 2, 3, and 4, respectively. Eleven RCTs were multicenter35, 36, 38–43, 45–47 and two single center;37, 44, 83 study centers were located primarily in North America and Europe. The majority of trials received funding from industry.35, 38, 41, 42, 45–47 Conflicts of interest were mainly in the form of grants or consulting fees from biomedical companies (e.g. Biosense Webster) and were disclosed by eight trials.35, 36, 38, 39, 42–44, 47, 83 Four RCTs reported no conflicts of interest37, 40, 41, 45 and one did not report whether any conflicts existed among its authors.46

Trial sample sizes ranged from 41 to 294 patients. The trial populations were predominantly male (59%–96%) and mean ages ranged from 51 to 64 years (Tables 2–4 below; detailed tables available in Appendix E, Tables E1–E3, E7–E9). Patients underwent treatment as a first-line therapy in three trials,35, 40, 42, 46 as a second-line therapy (i.e., had failed previous medical therapy) in eight36, 38, 40, 41, 43–45, 47, 83 and two studies included patients for whom treatment was either a first- or second-line therapy.37, 39 Four RCTs investigated outcomes in populations with comorbidities often seen in conjunction with AF: three were conducted specifically in patients with CHF (all with persistent AF)37, 39, 40 and one in patients with type 2 diabetes.36 No studies specifically targeted the Medicare population. The majority of studies required discontinuation of antiarrhythmic drug (AAD) use after the blanking period for the RFA group, while two studies permitted patients in the RFA group to remain on AADs throughout the followup period.40, 45 The most common AADs used in both the RFA and medical groups were amiodarone, propafenone, flecainide, and sotalol. Of the RCTs that included patients undergoing second-line therapy, medically-treated patients received new/previously unused AADs in four trials38, 40, 44, 47, 83 but it was unclear if this was the case in the other six.36, 37, 39, 41, 43, 45 The timing, duration and intensity of anticoagulation were variably reported across RCTs. In many studies, the adequacy of anticoagulation in the ablation group, particularly before ablation, was not clear. Limited detail regarding anticoagulation in the medical treatment groups was available.

Ablation strategies varied across studies. Pulmonary vein isolation (PVI) only was performed in one study,46 PVI plus additional lines (including the atrial roof, cavotricuspid and mitral isthmus, superior vena cava, foci from nonvenous structures, and other right and/or left atrial foci) in eleven,35, 36, 38–45, 47, 83 and PVI plus complex fractionated atrial electrogram (CFAE) and additional lines if necessary in one.37 PVI plus complex fractionated atrial electrogram (CFAE) was less common, but was completed in a subset of patients in four studies.39–42 In one study, additional RFA was performed specifically to resolve atrial flutter in combination with ablation for AF.40 Mapping systems were utilized in all studies. Details regarding ablation and mapping techniques used in each trial are outlined in Table H6 in the Appendix.

There was substantial crossover (37.0%–87.9%) from medical therapy to RFA in six trials35, 42–45, 47, 83 and two trials reported lower crossover rates of 9.4 percent38 and 3.8 percent.39 In some studies, a patient had to fail at least two drug treatments in order to be eligible for crossover. One trial did not provided the number of patients that crossed over, but indicated that followup could not be extended to 12 months in the medical therapy group because many went on to have ablation.37 One study did not report if crossover occurred40 and two did not allow crossover during the 12-month study period.36, 46 One RCT reported a crossover rate of 0 percent in the medical group compared with 35.7 percent in the ablation group during the study period; however, at the end of followup, 47.9 percent in the medical therapy group underwent RFA.41 A considerably smaller number of patients crossed over from ablation to medical therapy (0%– 9.4%) in seven RCTs.35, 38, 39, 41–44, 47

Only one trial was considered to be good quality;45 the remaining trials were all considered fair quality. Common methodological shortcomings included unclear allocation concealment (only one documented concealed allocation)45 and lack of assessor blinding for primary outcomes. Four RCTs did not report information on random sequence generation.38, 41, 44, 83 One RCT did not perform an intention-to-treat analysis.47 Discrepancies in baseline characteristics as well as unclear randomization methods were observed, although rarely.

Table 2 Patient characteristics and overview of study characteristics for RCTs comparing RFA with medical therapy in patients with paroxysmal atrial fibrillation

Author (Year) Therapy Sample Size | | Cosedis Nielsen (2012)35 RFA (n=146) | Cosedis Nielsen (2012)35 Medical (n=148) | Jais (2008)38 RFA (n=53) | Jais (2008)38 Medical (n=59) | Morillo (2014)42 RFA (n=66) | Morillo (2014)42 Medical (n=61) | Pappone (2006/ 2011)44, 83 RFA (n=99) | Pappone (2006/ 2011)44, 83 Medical (n=99) | Wilber (2010)47 RFA (n=106) | Wilber (2010)47 Medical (n=61) | Wazni (2005)46 RFA (n=33) | Wazni (2005)46 Medical (n=37)
Patient Demographics | Male, % (n) | 68.5 (100) | 71.6 (106) | 84.9 (45) | 83.1 (49) | 77.3 (51) | 73.8 (45) | 69.7 (69) | 64.6 (64) | 68.9 (73) | 62.3 (38) | NR | NR
Patient Demographics | Age (years); mean ± SD, mean (95% CI) | 56 ± 9 | 54 ± 10 | 49.7 ± 10.7 | 52.4 ± 11.4 | 56.3 ± 9.3 | 54.3 ± 11.7 | 55 ± 10 | 57 ± 10 | 55.5 (53.7–57.3) | 56.1 (52.9–59.4) | 53 ± 8 | 54 ± 8
Patient Demographics | AF duration; mean ± SD, median (IQR) | 6 ± 4 Years | 6 ± 5 years | 4.0 (1.0 – 12.0) hours^*^ (median, IQR) | 6.0 (2.0 – 15.0) hours^*^ (median, IQR) | NR | NR | 6 ± 4 Years | 6 ± 6 Years | 5.4 (4.3–6.5) years | 6.2 (4.6–7.9) years | 5 ± 2 months | 5 ± 2.5 months
Patient Demographics | Left atrial size (mm); mean ± SD, mean (95% CI) | 40 ± 6 | 38 ± 6 | 39.5 ± 5.6 | 40.0 ± 5.7 | 40 ± 5 | 43 ± 5 | 40 ± 6 | 38 ± 6 | 40.0 (38.9–41.1) | 40.5 (39.0–41.9) | 41 ± 8 | 42 ± 7
Patient Demographics | LVEF (%), mean ± SD, mean (95% CI) | [underlined: >60%:] 79.5 (n=116) [underlined: 40–60%:] 19.9 (n=29) | [underlined: >60%:] 81.8 (n=121) [underlined: 40–60%:] 17.6 (n=26) | 63.1 ± 11.0 | 65.6 ± 7.2 | 61.4 ± 4.8 | 60.8 ± 7.0 | 60 ± 8 | 61 ± 6 | 62.3 (60.4–64.3) | 62.7 (60.7–64.7) | 53 ± 5 | 54 ± 6
Patient Demographics | 1st/2nd line therapy | 1^st^ line | 1^st^ line | 2^nd^ line | 2^nd^ line | 1^st^ line | 1^st^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line | 1^st^ line | 1^st^ line
Patient Demographics | Special population | None | None | None | None | None | None | None | None | None | None | None | None
Comorbidities, % (n) | Heart failure | NR | NR | NR | NR | 3.0 (2) | 1.6 (1) | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | Hypertension | 29 (43) | 36 (53) | 21.6 (11) | 30.5 (18) | 42.4 (28) | 41.0 (25) | 56 (55) | 57 (56) | 48.6 (51) | 50.0 (30) | NR | NR
Comorbidities, % (n) | Coronary artery disease | 4 (6) | 1 (2) | NR | NR | 9.1 (6) | 3.3 (2) | 2 (2) | 2 (2) | NR | NR | NR | NR
Comorbidities, % (n) | Thyroid disease | 7 (10) | 7 (10) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | Pulmonary disease | 5 (8) | 4 (6) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | Valvular disease (moderate/severe) | 5 (7) | 10 (15) | NR | NR | NR | NR | 3 (3) | 1 (1) | NR | NR | NR | NR
Comorbidities, % (n) | History of prior stroke | 4 (6) | 3 (5) | NR | NR | 4.6 (3) | 6.6 (4) | NR | NR | 1.9 (2)^†^ | 5.0 (3)^†^ | NR | NR
Comorbidities, % (n) | Prior embolic/thromboembolic event | NR | NR | 1.9 (1) | 11.9 (7) | NR | NR | NR | NR | 1.9 (2) | 3.3 (2) | NR | NR
Comorbidities, % (n) | CHADS2 score 2+ | 12 (17) | 13 (19) | NR | NR | 6.1 (4) | 11.5 (7) | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | Diabetes | 4 (6) | 10 (10) | 1.9 (1) | 3.4 (2) | 1.5 (1) | 6.6 (4) | 5.1 (5) | 4.0 (4) | 9.5 (10) | 11.7 (7) | NR | NR
Comorbidities, % (n) | Structural heart disease | NR | NR | 19 (10) | 24 (14) | NR | NR | 2.0 (2) | 1.0 (1) | 9.5 (10) | 15.0 (9) | 25 (8) | 28 (10)
Study Characteristics | Followup period | 24 months | 24 months | 12 months | 12 months | 24 months | 24 months | 2006: 12 months 2011: 48 months | 2006: 12 months 2011: 48 months | 12 months | 12 months | 12 months | 12 months
Study Characteristics | Completed followup, % (n) | 94.5 (138) | 92.6 (137) | 98.1 (52) | 93.2 (55) | 86.4 (57) | 78.7 (48) | 2006: 100 2011: 95 (94)^‡^ | 2006: 100 2011: 95 (94)^‡^ | NR | NR | 97 (32) | 94.6 (35)
Study Characteristics | Blanking period | 3 months | 3 months | 3 months | 3 months | 3 months | 3 months | 6 weeks | 6 weeks | 3 months | 14 days | 2 months | 2 months
Study Characteristics | Crossover, % (n) | 9 (13) | 37 (54) | 9.4 (5) | 62.7 (37) | 9.1 (6) | 42. (26) | 5.1 (5) | 42.4 (42) | 4.8 (5) | 60 (36) | Not allowed during F/U (>1 year: 3.1 (1) | Not allowed during F/U (>1 year: 51.4 (18)
Study Characteristics | Use of AADs in RFA group | NR | --- | NR | --- | Stopped after blanking period | --- | Stopped after blanking period | --- | Previously ineffective drug^§^ | --- | Beta-blocker^§^ | ---

AAD = antiarrhythmic drug; AF = atrial fibrillation; CHADS2: = Cardiac failure, Hypertension, Age, Diabetes, Stroke system; F/U = followup; IQR = interquartile range; LVEF = left ventricular ejection fraction; NR = not reported; RCTs = nonrandomized controlled trials; RFA = radiofrequency ablation; SD = standard deviation.

* Authors report duration of episodes, not the length of time since the person was diagnosed with AF.

† Cerebrovascular accident/TIA.

‡ 95% followup for the entire study group at 4 years, 100% followup to 3 years.

§ At physicians discretion during effectiveness period.

Table 3 Patient characteristics and overview of study characteristics for RCTs comparing RFA with medical therapy in patients with persistent atrial fibrillation

Author (Year) Therapy Sample Size | | MacDonald (2011)40 RFA (n=22) | MacDonald (2011)40 Medical (n=19) | Mont (2013)41 RFA (n=98) | Mont (2013)41 Medical (n=48) | Oral (2006)43 RFA (n=77) | Oral (2006)43 Medical (n=69) | Jones (2013)39 RFA (n=26) | Jones (2013)39 Medical (n=26) | Hunter (2014)37 RFA (n=26) | Hunter (2014)37 Medical (n=24)
Patient Demographics | Male, % (n) | 77.3 (17) | 78.9 (15) | 77.5 (76) | 77.1 (37) | 87.0 (67) | 89.9 (62) | 80.8 (21) | 92.3 (24) | 92.6 (25) | 95.8 (23)
Patient Demographics | Age (years); mean ± SD | 62.3 ± 6.7 | 64.4 ± 8.3 | 55 ± 9 | 55 ± 9 | 55 ± 9 | 58 ± 8 | 64 ± 10 | 62 ± 9 | 55 ± 12 | 60 ± 10
Patient Demographics | AF duration (years); mean ± SD | 3.7 ± 3.0 | 5.3 ± 3.9 | NR | NR | 5 ± 4 | 5 ± 4 | 4.3 ± 3.3 | 4.3 ± 6.3 | 2.0 (IQ range, 1.4–2.8) | 2.0 (IQ range, 1.0–4.0)
Patient Demographics | Left atrial size (mm); mean ± SD | NR | NR | 41.3 +/− 4.6 | 42.7 +/− 5.1 | 45 +/− 6 | 45 +/− 5 | 50 ± 6 | 46 ± 7 | 52 ± 11 | 50 ± 10
Patient Demographics | LVEF (%), mean ± SD | 16.1 ± 7.1 | 19.6 ± 5.5 | 61.1 ± 8.8 | 60.8 ± 9.7 | 55 ± 7 | 56 ± 7 | 22 ± 8 | 25 ± 7 | 31.8 ± 7.7 | 33.7 ± 12.1
Patient Demographics | 1st/2nd line therapy | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line | Both | Both | Both | Both
Patient Demographics | Special population | Heart Failure | Heart Failure | None | None | None | None | Heart failure | Heart failure | Heart failure | Heart failure
Comorbidities, % (n) | Heart failure | 100 (22) | 100 (19) | NR | NR | NR | NR | 100 (26) | 100 (26) | 100 (26) | 100 (24)
Comorbidities, % (n) | Hypertension | 64 (14) | 58 (11) | 46.9 (46) | 39.5 (19) | NR | NR | NR | NR | 31 (8) | 33 (8)
Comorbidities, % (n) | Coronary artery disease | 50 (11) | 53 (10) | NR | NR | 4 (3) | 6 (4) | 42 (11) | 50 (13) | 23 (6) | 29 (7)
Comorbidities, % (n) | Cardiomyopathy | NR | NR | NR | NR | 3 (2) | 1 (1) | NR | NR | 31 (8) | 29 (7)
Comorbidities, % (n) | Pulmonary disease | 27 (6) | 16 (3) | 3.1 (3) | 2.1 (1) | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | Obstructive sleep apnea | NR | NR | 10.2 (10) | 16.6 (8) | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | Valvular disease (moderate/severe) | NR | NR | NR | NR | 1 (1) | 0 (0) | NR | NR | NR | NR
Comorbidities, % (n) | History of prior stroke | NR | NR | 3.1 (3) | 2.1 (1) | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | History of prior TIA | NR | NR | 1.0 (1) | 2.1 (1) | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | Diabetes | 32 (7) | 21 (4) | NR | NR | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | NYHA functional class II | 2 (9) | 2 (11) | NR | NR | NR | NR | 14 (54) | 13 (50) | 42 (11) | 50 (12)
Comorbidities, % (n) | NYHA functional class III | 20 (91) | 17 (89) | NR | NR | NR | NR | 12 (46) | 13 (50) | 58 (15) | 50 (12)
Study Characteristics | Followup period | 6 Months | 6 Months | 12 months | 12 months | 12 months | 12 months | 12 months | 12 months | 6 months^*^ | 6 months^*^
Study Characteristics | Completed followup, % (n) | 90.9 (20) | 94.7 (18) | 91.8 (90) | 100 (48) | 100 (77) | 100 (69) | 92.3 (24) | 100 (26) | 96 (25) | 96 (23)
Study Characteristics | Blanking period | 3 months | NR | 3 months | 3 months | NR | NR | 2 months | NR | 3 months | 3 months
Study Characteristics | Crossover, % (n) | NR | NR | 35.7 (35) | 47.9 (23) | 0 (0) | 77 (53) | 3.8 (1) | 3.8 (1) | NR | NR
Study Characteristics | Use of AADs in RFA group | Yes (amiodarone) | --- | Yes (amiodarone, class Ic, or class III drugs) | --- | 1% (1/77) continued amiodarone. | --- | NR | --- | No (stopped post-ablation; AAD type NR) | ---

AAD = antiarrhythmic drug; AF = atrial fibrillation; LVEF = left ventricular ejection fraction; NR = not reported; NYHA = New York Heart Association; RCT = randomized controlled trial; RFA = radiofrequency ablation; SD = standard deviation; TIA = transient ischemic attack.

* Followup was extended to 1 year in the ablation group only; this could not be performed in the medical group because many went on to have pulmonary vein isolation, atrioventricular node ablation, and device implantation.

Table 4 Patient characteristics and overview of study characteristics for RCTs comparing RFA with medical therapy in patients with paroxysmal or persistent atrial fibrillation

Author (Year) Therapy Sample Size | | Forleo (2009)36 RFA (n=35) | Forleo (2009)36 Medical (n=35) | Stabile (2006)45 RFA (n=68) | Stabile (2006)45 Medical (n=69)
Patient demographics | Male, % (n) | 57.1 (20) | 65.7 (23) | 54.4 (37) | 63.8 (44)
Patient demographics | Age (years); mean ± SD | 63.2 ± 8.6 | 64.8 ± 6.5 | 62.2 ± 9 | 62.3 ± 10
Patient demographics | Paroxysmal AF, % (n) | 45.7 (16) | 37.1 (13) | 61.8 (42) | 72.5 (50)
Patient demographics | Persistent AF, % (n) | 54.3 (19) | 62.9 (22) | 38.2 (26) | 27.5 (19)
Patient demographics | AF duration (years); median (IQR) or mean ± SD | 3.4 (1.5–5.5) | 3.0 (1.4–4.6) | 5.1 ± 3.9 | 7.1 ± 5.9
Patient demographics | Left atrial size (mm); mean ± SD | 44.3 ± 5.6 | 45.2 ± 5.2 | 46 ± 5 | 45.4 ± 5.5
Patient demographics | LVEF (%), mean ± SD | 54.6 ± 7 | 52.6 ± 8.6 | 59.1 ± 6.7 | 57.9 ± 5.8
Patient demographics | 1st/2nd line therapy | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line
Patient demographics | Special population | Diabetes | Diabetes | None | None
Comorbidities, % (n) | Hypertension | 62.9 (22) | 68.6 (24) | 52.9 (36) | 49.3 (34)
Comorbidities, % (n) | Coronary artery disease | 20.0 (7) | 20.0 (7) | NR | NR
Comorbidities, % (n) | Hypertrophic cardiomyopathy | Dilated: 8.6 (3) | Dilated: 5.7 (2) | Dilated: 1.5 (1) Ischemic: 4.4 (3) Valvular: 4.4 (3) | Dilated: 2.9 (2) Ischemic: 7.2 (5) Valvular: 2.9 (2)
Comorbidities, % (n) | Valvular disease (moderate/severe) | 5.7 (2) | 11.4 (4) | NR | NR
Comorbidities, % (n) | History of prior stroke | 14.3 (5) | 8.6 (3) | NR | NR
Comorbidities, % (n) | Diabetes | 100 (35) | 100 (35) | NR | NR
Comorbidities, % (n) | Structural heart disease | 45.7 (16) | 54.3 (19) | 63.2 (43) | 62.3 (43)
Comorbidities, % (n) | Lung disease (asthma/COPD) | 2.9 (1) | 2.9 (1) | NR | NR
Study characteristics | Followup period | 12 months | 12 months | 12 months | 12 months
Study characteristics | Completed followup, % (n) | 100 (35) | 100 (35) | 97.1 (66) | 97.1 (67)
Study characteristics | Blanking period | 5 weeks | 5 weeks | 1 month | 1 month
Study characteristics | Crossover, % (n) | None permitted | None permitted | NR | 52.2 (36)
Study characteristics | Use of AADs in RFA group | NR | --- | Yes–various | ---

AAD = antiarrhythmic drug; AF = atrial fibrillation; COPD = chronic obstructive pulmonary disease; IQR = interquartile range; LVEF = left ventricular ejection fraction; NR = not reported; RFA = radiofrequency ablation; SD = standard deviation.

##### Comparative Observational Studies

Seven comparative observational studies, three prospective48, 49, 52 and four retrospective50, 51, 53, 54 compared RFA with medical therapy. Of these, three reported outcomes up to 12 months following the blanking period49, 52, 54 and four reported on outcomes after 12 months (15 to 69 months).48, 50, 51, 53 Three studies only included paroxysmal AF patients,49, 52, 54 one only included persistent AF patients,48 and three studies included patients with either paroxysmal or persistent AF;50, 51, 53 study characteristics are presented in Tables 5, 6, and 7, respectively. All studies included patients receiving treatment as a second-line therapy (i.e., had failed previous medical therapy). Five studies reported blanking periods ranging from 1 to 3 months in the RFA group.48, 49, 51, 52, 54 The remaining two studies did not report a blanking period.50, 53 Funding was not reported for four studies;48, 51, 53, 54 one study was supported by Biosense Webster50 and two received government grants/funds (the Health Research Foundation/Health Bureau of Chongquing49 and the National Science Foundation of China and Beijing Natural Science Foundation52). Two studies reported a conflict of interest (COI) regarding the first author’s relationship with Biosense Webster,48, 50 while three studies indicated they had no disclosures49, 52, 54 and two did not report COI.51, 53

The study populations were predominantly male (49.5%–84.7%) and mean ages ranged from 55 to 75 years (Tables 5–7 below; detailed tables can be found in Appendix E, Tables E4–E6, E10–E12). Two studies were comprised of exclusively Medicare populations (age ≥65 years).48, 53 All but two studies49, 50 reported hypertension in over half of their patients; otherwise, the comorbidities and their prevalence varied across studies.

Ablation strategies varied (details regarding ablation and mapping techniques used in each study are outlined in Table H6 in the Appendix). All patients underwent PVI, with three studies reporting subsequent ablation of other areas (i.e., cavotricuspid isthmus, roofline, metrial annulus, superior vena cava).48, 50, 51 Two studies allowed for the use of AADs throughout the study period,50, 53 with the remaining five studies requiring patients to cease AAD use after the blanking period. Common AADs included amiodarone, flecainide, propafenone, and sotalol.

Of the seven studies, four were fair quality48–50, 52 and three were poor quality.51, 53, 54 The most common methodological shortcoming was a lack of assessor blinding for primary outcomes. Followup of at least 80 percent was reported by three studies48, 52, 54 and all of them controlled for confounding (primarily in the form of similar baseline characteristics between groups).49–54

Table 5 Patient characteristics and overview of study characteristics for comparative observational studies comparing RFA with medical therapy in patients with paroxysmal atrial fibrillation

Author (Year) Therapy Sample Size | | Lan (2009)^*^ Prospective49 RFA (n=120) | Lan (2009)^*^ Prospective49 Medical (n=120) | Sang (2013)^†^ Prospective52 RFA (n=85) | Sang (2013)^†^ Prospective52 Medical (n=90) | Yu (2012)^†^ Retrospective54 RFA (n=98) | Yu (2012)^†^ Retrospective54 Medical (n=112)
Patient Demographics | Male, % (n) | 66.7 (80) | 64.2 (77) | 67.1 (55) | 69.1 (58) | 49.5 (48) | 52.0 (53)
Patient Demographics | Age (years); mean ± SD | 59.5 | 58.5 | 55.9 ± 6.1 | 57.2 ± 5.4 | 55.2 ± 6.5 | 54.9 ± 7
Patient Demographics | AF duration (years); mean ± SD | 2.6 | 2.6 | 7.5 ± 7.5 | 7.2 ± 7.6 | 2.4 ± 0.1 | 2.3 ± 0.1
Patient Demographics | Left atrial size (mm); mean ± SD | 34.7 | 34.7 | 39.0 ± 5.9 | 38.6 ± 6.2 | 31.7 ± 1.9 | 32 ± 2
Patient Demographics | LVEF (%), mean ± SD | 66.5 | 66.6 | 59.6 ± 7.5 | 58.9 ± 8.3 | 57.9 ± 6.4 | 56.9 ± 6
Patient Demographics | 1st/2nd line therapy | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line
Patient Demographics | Special population | None | None | LVEF <35% | LVEF <35% | None | None
Comorbidities, % (n) | Hypertension | NR | NR | 64.6 (53) | 60.7 (51) | 54.1 (53) | 56.9 (58)
Comorbidities, % (n) | Coronary artery disease | NR | NR | 9.8 (8) | 11.9 (10) | 3.1 (3) | 5.9 (6)
Comorbidities, % (n) | Hypertrophic cardiomyopathy | NR | NR | [underlined: Dilated]: 2.4 (2) | [underlined: Dilated]: 4.8 (4) | NR | NR
Comorbidities, % (n) | Valvular disease (moderate/severe) | NR | NR | 3.7 (3) | 6.0 (5) | NR | NR
Comorbidities, % (n) | History of prior stroke | NR | NR | 8.5 (7) | 8.3 (7) | 6.1 (6) | 7.8 (8)
Comorbidities, % (n) | BMI (kg/m^2^), mean | 23.9 | 24.5 | NR | NR | NR | NR
Comorbidities, % (n) | Diabetes | NR | NR | 13.4 (11) | 19.1 (16) | 4.1 (4) | 8.2 (9)
Comorbidities, % (n) | Current smoker | NR | NR | NR | NR | 38.8 (38) | 33.3 (34)
Comorbidities, % (n) | Current drinker | NR | NR | NR | NR | 18.4 (18) | 20.6 (21)
Study Characteristics | Followup period | 12 months | 12 months | 312 months | 12 months | 12 months | 12 months
Study Characteristics | Completed followup, % (n) | NR | NR | 96.5 (82) | 93.3 (84) | 98.9 (97) | 91.1 (102)
Study Characteristics | Blanking period | 1 month | 1 month | 3 months | NR | 3 months | NR
Study Characteristics | Use of AADs in RFA group | NR | --- | 2 months after ablation and then discontinued if no AF recurred | --- | Stopped after blanking period | ---

AAD = antiarrhythmic drug; AF = atrial fibrillation; BMI = body mass index; LVEF = left ventricular ejection fraction; NR = not reported; RFA = radiofrequency ablation; SD = standard deviation.

* The circumferential pulmonary vein ablation (n=60) and the segmental pulmonary vein isolation (n=60) groups were combined to form one ablation group. Age, AF duration, left atrial size, LVEF, and BMI were calculated using weighted means.

† Demographics reported out of the number of patients who completed followup.

Table 6 Patient characteristics and overview of study characteristics for comparative observational studies comparing RFA with medical therapy in patients with persistent atrial fibrillation

Author (Year) Therapy Sample Size | | Blandino (2013) Prospective48 RFA (n=153) | Blandino (2013) Prospective48 Medical (n=259)
Patient Demographics | Male, % (n) | 71 (109) | 72 (186)
Patient Demographics | Age (years); mean ± SD | 75 ± 5 | 76 ± 5
Patient Demographics | AF duration (months); mean ± SD | 6 ± 4 months | 6 ± 4 months
Patient Demographics | Left atrial size (mm); mean ± SD | 47 ± 5 | 47 ± 6
Patient Demographics | LVEF (%), mean ± SD | 56 ± 6 | 56 ± 8
Patient Demographics | 1st/2nd line therapy | 2^nd^ line | 2^nd^ line
Patient Demographics | Special population | Medicare population | Medicare population
Comorbidities | Hypertension | 70 (107) | 74 (191)
Comorbidities | Prior thyroid dysfunction | 27 (41) | 21 (53)
Comorbidities | History of prior stroke or TIA | 17 (26) | 14 (36)
Comorbidities | Diabetes | 3 (5) | 6 (15)
Comorbidities | Dyslipidemia | 24 (36) | 26 (68)
Comorbidities | Structural heart disease | [underlined: Ischemic]: 14 (21) [underlined: Valvular]: 5 (8) [underlined: Others]: 5 (7) | [underlined: Ischemic]: 13 (34) [underlined: Valvular]: 9 (22) [underlined: Others]: 2 (5)
Study Characteristics | Followup period | mean 60 ± 17 months | mean 60 ± 17 months
Study Characteristics | Complete followup, % (n) | 100 (153) | 100 (259)
Study Characteristics | Blanking period | 3 months | NR
Study Characteristics | Use of AADs in RFA group | All patients continued the same AAD regimen during blanking period; then, according to AF/AT recurrence, referring physician's decision, and patient's will AADs were suspended or not | ---

AAD = antiarrhythmic drug; AF = atrial fibrillation; LVEF = left ventricular ejection fraction; NR = not reported; RFA = radiofrequency ablation; SD = standard deviation.

Table 7 Patient characteristics and overview of study characteristics for comparative observational studies comparing RFA with medical therapy in patients with paroxysmal, persistent or permanent atrial fibrillation

Author (Year) Therapy Sample Size | | Reynolds (2012) Retrospective50 RFA (n=801) | Reynolds (2012) Retrospective50 Medical (n=801) | Rossillo (2008) Retrospective51 RFA (n=85) | Rossillo (2008) Retrospective51 Medical (+Cardioversion) (n=85) | Sonne (2009) Retrospective53 RFA^*^ (n=146) | Sonne (2009) Retrospective53 Medical (+ Cardioversion) (n=205)
Patient Demographics | Male, % (n) | 60.9 (488) | 62.6 (501) | 84.7 (72) | 84 .7 (72) | 67.8 (99) | 68.8 (141)
Patient Demographics | Age (years); mean ± SD | [underlined: ≥65 yrs]: 48.2 (386) | [underlined: ≥65 yrs]: 43.9 (352) | 62.0 ± 7.6 | 62.0 ± 7.6 | 67.2 ± 8.0 | 66.7 ± 7.7
Patient Demographics | Paroxysmal AF, % (n) | NR | NR | 31.7 (27) | 0 (0) | 26.7 (39) | 24.8 (51)
Patient Demographics | Persistent AF, % (n) | NR | NR | 50.5 (43) | 100.0 (85) | NR^†^ | NR^†^
Patient Demographics | Permanent AF, % (n) | NR | NR | 17.8 (15) | 0 (0) | NR^†^ | NR^†^
Patient Demographics | AF duration (years); mean | NR | NR | 8 (range, 1–24) | Unknown | NR | NR
Patient Demographics | Left atrial size (mm); mean ± SD | NR | NR | 44 ± 6 | 42 ± 7 | 55 ± 8.7 | 56 ± 8.7
Patient Demographics | LVEF (%), mean ± SD | NR | NR | 58 ± 6 | 56 ± 8 | 50 ± 9 | 50 ± 10
Patient Demographics | 1st/2nd line therapy | 2^nd^ line | 2^nd^ line | 2^nd^ line | NR | 2^nd^ line | 2^nd^ line
Patient Demographics | Special population | None | None | None | None | Medicare population | Medicare population
Comorbidities, % (n) | Heart failure | 17.4 (139) | 15.7 (126) | NR | NR | NR | NR
Comorbidities, % (n) | Hypertension | 42.7 (342) | 40.7 (326) | NR | NR | 56.8 (83) | 57 (117)
Comorbidities, % (n) | Coronary artery disease | 37.0 (296) | 35.6 (285) | NR | NR | 44.5 (65) | 31.7 (65)
Comorbidities, % (n) | Cardiomyopathy | 7.5 (60) | 7.2 (58) | NR | NR | NR | NR
Comorbidities, % (n) | Kidney disease | 1.9^§^ (15) | 2.1^§^ (17) | NR | NR | 6.1 (9) | 4.9 (10)
Comorbidities, % (n) | Valvular disease (moderate/severe) | 24.6 (197) | 21.5 (172) | 2.4 (2) | 2.4 (2) | NR | NR
Comorbidities, % (n) | History of prior MI | 1.6 (13) | 2.1 (17) | NR | NR | 17 (25) | 15.1 (31)
Comorbidities, % (n) | History of prior stroke/TIA | 2.9 (23) | 4.1 (33) | NR | NR | NR | NR
Comorbidities, % (n) | Diabetes | 18.7 (150) | 15.2 (122) | NR | NR | 19.8 (29) | 20.0 (41)
Comorbidities, % (n) | Structural heart disease | 3.0 (24) | 1.8 (15) | 71.8 (61) | 71.8 (61) | NR | NR
Comorbidities, % (n) | COPD | 10.2 (82) | 11.4 (91) | NR | NR | NR | NR
Study Characteristics | Followup period (months) | Mean 27 | Mean 27 | mean 15 ± 7 | mean 16 ± 7 | mean: 69 ± 27 | mean: 69 ± 27
Study Characteristics | Completed followup, % (n) | NR | NR | NR | NR | 97.9 (143) | 83.4 (171)
Study Characteristics | Blanking period | NR | NR | 8 weeks | NR | NR | NR
Study Characteristics | Use of AADs in RFA group | Yes, various | --- | None unless recurrence developed | --- | Yes, various | ---

AAD = antiarrhythmic drug; AF = atrial fibrillation; COPD = chronic obstructive pulmonary disease; LVEF = left ventricular ejection fraction; MI = myocardial infarction; NR = not reported; RFA = radiofrequency ablation; SD = standard deviation.

* Two ablation groups were reported in this paper. Only the group that underwent pulmonary vein antrum isolation was included; the atrioventricular junction ablation group was excluded from our analysis per our prespecified exclusion criteria.

† Reported as nonparoxysmal AF: ablation (73.2%, n=107); medical (75.1%; n=154).

#### Detailed Synthesis

##### Primary Outcomes

###### Mortality >30 days

Seven RCTs comparing RFA with medical therapy reported all-cause mortality past the 30 day periprocedural time up to 12 (or 13)45 months or for which timing of mortality was not reported.38, 39, 41, 43, 45–47 RFA was used as a first-line treatment in only one of these trials.46 Of the seven RCTs, three fair-quality trials evaluated patients with paroxysmal AF,38, 46, 47 three fair-quality trials evaluated patients with persistent AF,39, 41, 43 and one good-quality trial included both paroxysmal and persistent AF patients.45 Two fair-quality trials evaluated all-cause mortality up to 24 months past the 30 day periprocedural period in patients with paroxysmal AF.35, 42 The majority of patients across studies were male with mean ages ranging from 51 to 64 years old. Study sizes were likely insufficient to effectively determine the effect of AF ablation on mortality or detect statistical differences between treatment groups.

Overall, all-cause mortality within 12 months was rare across the seven trials, ranging from 0 to 3.8 percent in RFA groups and 0 to 2.9 percent in groups receiving medical therapy (Figure 3). Data for this outcome were sparse and were not pooled given inconsistency across studies with regard to which treatment may be favored for specific AF types and across AF types. Crossover from medical therapy to RFA was substantial in most studies, ranging from 37 to 88 percent across studies.

All-cause mortality within 24 months was also rare across two studies of patients with paroxysmal AF (Table 8). One trial reported no mortality in either treatment group,42 the other reported two deaths (1.4%) in the RFA group and four (2.9%) in the medical treatment group.35

Of the six included observational studies, three reported all-cause mortality (Table 9). One fair-quality study, conducted in a Medicare-relevant population (age ≥75 years) of persistent AF patients, reported similar low rates of all-cause mortality in both groups at a mean followup of 60 months, all of which were cardiovascular-related.48 The remaining two studies included patients with a mixture of AF types. In one poor-quality study with a mean followup of 16 months, no patient died in the ablation arm and one patient (1.2%) in the medical therapy arm died from a stroke (difference not statistically significant).51 In the second study, conducted in a Medicare-relevant population (mean age 67 years), three patients (2.1%) in the ablation group and 34 patients (16.5%) in the medical therapy group had died at the end of 69 months of follow up (HR 0.20; 95% CI 0.06 to 0.69; p=0.01).53 All deaths in the ablation group were cardiovascular-related. Although this last study provided evidence of a survival benefit in the ablation arm, the limitations of this poor-quality study included lack of information about blinding of outcome assessor’s regarding intervention, lack of full reporting of prespecified outcomes, and no reporting on attrition rates.

Figure 3 Profile likelihood model meta-analysis of all-cause mortality and myocardial infarction within 12 months* of followup in RCTs comparing RFA with medical therapy

MI = myocardial infarction; RCT = randomized controlled trial; RFA = radiofrequency catheter ablation; RR = relative risk.

*For Stabile 2006, followup time included a 1-month blanking period, for a total of 13 months followup.

Figure 3. This figure is a forest plot that displays all-cause mortality and myocardial infarction (MI) following radiofrequency ablation (RFA) compared with medical therapy from seven randomized controlled trials (RCTs) with followup periods of 12 months or less. For the outcome of all-cause mortality, three trials were in patients with paroxysmal AF, three in patients with persistent AF, and one trial was in a mixed population. Data for this outcome were sparse and were not pooled given inconsistency across studies with regard to which treatment may be favored for specific AF types and across AF types. Overall, all-cause mortality within 12 months was rare across the seven trials, ranging from 0 to 3.8 percent in RFA groups and 0 to 2.9 percent in groups receiving medical therapy. Two of these RCTs, both in paroxysmal AF, also reported MI up to 12 months of follow-up. A total of two patients experienced fatal MI, one in each treatment group.

###### Cardiovascular Mortality >30 Days

Cardiovascular mortality past the 30 day periprocedural time through 12 months followup was reported in five RCTs, three of which included only paroxysmal AF patients38, 46, 47 and two of which included only persistent AF patients.39, 41 One trial of persistent AF patients included only heart failure patients with an ejection fraction less than 50 percent.39 Two studies reported cardiovascular mortality up to 24 months past the 30 day periprocedural time.35, 42 All trials were rated as fair quality. Study sizes were likely insufficient to effectively determine risk of cardiovascular mortality or detect statistical differences between treatment groups.

Cardiovascular mortality was rare at both 12-month and 24-month time frames (Table 8). Across three RCTs of paroxysmal AF patients, one event in each treatment group was reported within 12 months of followup. Both deaths were from myocardial infarction and not attributed to treatment.38, 46, 47 Across two trials of paroxysmal patients with 24 months of followup, one cardiovascular death occurred in the medical therapy group and none in the RFA group.

In individuals with persistent AF, one cardiovascular death was reported in the RFA group across two RCTs with followup to 12 months.39, 41 This death occurred in the study that was restricted to patients with heart failure.39

Two observational studies, both conducted in Medicare-relevant populations (age ≥65 years), assessed cardiovascular mortality greater than 30 days from treatment (Table 9). In one fair-quality study of patients with persistent AF, two patients (1.3%) in the RFA group and five patients (1.9%) in the medical therapy group died from cardiovascular causes during a mean followup of 60 months (p=0.714).48 In the second, poor-quality study of patients with mixed AF, after 69 months of followup, three patients (2.1%) in the RFA arm and 20 patients (9.8%) in the medical therapy arm had died from cardiovascular causes.53

###### Stroke >30 Days

Four fair-quality trials comparing RFA with medical therapy reported on stroke past the 30 day periprocedural time, three of which had 12 months of followup36, 41, 46 and one of which had 24 months of followup.42 Of the trials reporting stroke up to 12 months, one was in patients with paroxysmal AF,46 one in patients with persistent AF,41 and the third trial did not separate data by AF type, resulting in a population that combined patients with paroxysmal and persistent AF (this trial included only patients with diabetes).36 None of the trials provided criteria or definitions for stroke diagnosis although all distinguished it from TIA. Anticoagulation was used in all patients receiving RFA and its use was variably reported for the medical groups. Duration of anticoagulation use varied across studies. In three of the studies,41, 42, 46 it was not clear that anticoagulation prior to ablation was adequate, but it appeared to be adequate during the procedure. Anticoagulation was discontinued in the absence of AF recurrence at 3 months (and no pulmonary vein narrowing ≥50%)46 or 6 months (and no major risk factors),36 a practice that is not supported by strong evidence.

No strokes were observed in any of the three trials with followup to 12 months or in the trial which followed patients to 24 months (Table 8). Study sizes were likely insufficient to effectively determine effect of AF ablation on stroke.

Four of the observational studies assessed stroke greater than 30 days from treatment (Table 9). Three studies were of patients with mixed AF. No strokes occurred in the ablation group in two poor-quality studies compared with four (4.7%)51 and three (1.5%)53 strokes in the medical therapy groups, during followup periods of 16 and 69 months, respectively. The latter study was comprised of patients with a mean age of 67 years (i.e., a Medicare-relevant population). In the third fair-quality administrative database study, patients in the ablation arm suffered any stroke/TIA at an annualized rate of 3.4 percent while those who underwent medical therapy had a rate of 5.5 percent.50 Unadjusted hazard ratio for stroke/TIA of ablation versus medical therapy was 0.62 (95% CI 0.44 to 0.86; p=0.005). The multivariable Cox proportional hazards model also demonstrated an association between age ≥65 years and stroke/TIA after adjustment for other variables. A fourth, fair-quality study conducted in a Medicare-relevant population (age ≥75 years) of persistent AF patients, reported the incidence of stroke or TIA; two patients in the ablation arm and five patients in the medical therapy group suffered an event after a mean of 60 months (1.3% vs. 1.9%, respectively; p=0.714).48 The adequacy of anticoagulation before and after ablation in two studies cannot be assessed based on authors’ descriptions,51, 53 but appeared to be adequate in the two studies that reported on the combined outcome of stroke or TIA.48, 50

###### Myocardial Infarction >30 Days

Three trials reported on MI past the 30 day periprocedural time, two with followup to 12 months38, 47 and one with followup to 24 months.35 RFA was a second-line treatment in both trials. None of the trials provided diagnostic criteria used for determining MI.

All trials were in patients with paroxysmal AF. A total of two patients experienced fatal MI, one in each treatment group, up to 12 months of followup across two studies (Figure 3, above; Table 8).38, 47 One fatal MI in the medical treatment group was reported in the one study with 24-month followup (Table 8).35

Two observational studies, both conducted in Medicare-relevant populations (age ≥65 years), assessed MIs occurring greater than 30 days from treatment (Table 9). In one fair-quality study of persistent AF,48 no patients in the RFA arm and one patient (0.4%) in the medical therapy arm suffered an MI during a mean followup of 60 months (p=1.0) while in the second poor-quality study (in a mixed AF population),53 two patients in the RFA arm (1.4%) compared with no patients in the medical therapy arm had a MI after 69 months of followup.

###### Transient Ischemic Attack >30 Days

Six trials comparing RFA with medical therapy reported frequency of TIA after the 30 day periprocedural period. All but one study was considered to be of fair quality. For followup to 12 months, there was one trial in patients with paroxysmal AF,46 one trial in patients with persistent AF,41 and two trials that enrolled patients with either paroxysmal or persistent AF.36, 45 One trial included a 1-month blanking period, for a total followup period of 13 months.45 One of these trials consisted only of patients with diabetes.36 Two trials in patients with paroxysmal AF reported on TIA at followup longer than 12 months.35, 83 None of the studies provided definitions or details regarding evaluation or diagnosis for TIA.

Across all RCTs, TIA was rare with a frequency ranging from 0.7 to 1.4 percent, regardless of treatment (Table 8).

Of the six included observational studies, none specifically assessed TIA greater than 30 days from treatment.

###### Congestive Heart Failure

Only one fair-quality trial comparing RFA with medical therapy reported on development of CHF.35 None of the patients receiving RFA developed CHF compared with two patients (1.4%) in the medical group by 24 months of followup (Table 8).

Two comparative observational studies, both in Medicare-relevant populations (age ≥65 years) assessed CHF. In one fair-quality study in persistent AF patients, no patient in the RFA group compared with three patients in the medical group suffered heart failure during a mean followup of 60 months (p=0.297),48 while in the second poor-quality study (in a mixed AF population)53 one (0.7%) RFA patient compared with 20 (9.8%) medical therapy patients suffered heart failure (Table 9). A third fair-quality observational administrative database study in the general population reported a lower annualized rate of hospitalization for heart failure (1.5%) following RFA versus the medical treatment arm (2.2%). The Cox regression unadjusted hazard ratio for heart failure hospitalization in the ablation versus medical treatment cohorts was 0.69 (95% CI 0.42 to 1.15, p=0.158). In multivariable models, there was no association between age ≥65 years and rates of hospitalization for heart failure at 27 months.

###### Progression from Paroxysmal to Persistent Atrial Fibrillation

One small, fair-quality trial, in which RFA was used as a second-line therapy, followed patients up to 48 months and reported the progression from paroxysmal AF to persistent AF.83 Significantly more patients originally randomized to the medical therapy group had progression to persistent AF compared with those receiving RFA (19.2% vs. 1.0%; RR 0.09, 95% CI 0.01 to 0.61, p<0.0001) (Table 8). Crossover from medical therapy to RFA in this study was 42 percent and it is not clear how this may have been considered in determining progression.

Of the six included observational studies, none assessed progression from paroxysmal to persistent AF.

Table 8 Primary efficacy outcomes for RCTs comparing RFA with medical therapy^*^

Outcome^†^ | AF Type (1^st^/2^nd^ line therapy) | Study | Followup | RFA % (n/N) | Medical Therapy % (n/N)
Mortality (all-cause) >30 days | Paroxysmal (1^st^ line) | Morillo 2014^42^ | 24 months | 0% (0/66) | 0% (0/61)
Mortality (all-cause) >30 days | Paroxysmal (1^st^ line) | Cosedis Nielsen 2012^35^ | 24 months | 1.4% (2/140)^‡^ | 2.9% (4/141)^‡^
Mortality (cardiovascular) >30 days | Paroxysmal (1^st^ line) | Wazni 2005^46^ | 12 months | 0% (0/32) | 0% (0/35)
Mortality (cardiovascular) >30 days | Paroxysmal (1^st^ line) | Morillo 2014^42^ | 24 months | 0% (0/66) | 0% (0/61)
Mortality (cardiovascular) >30 days | Paroxysmal (1^st^ line) | Cosedis Nielsen 2012^35^ | 24 months | 0% (0/138) | 0.7% (1/138)^‡^
Mortality (cardiovascular) >30 days | Paroxysmal (2^nd^ line) | Jais 2008^38^ | 12 months | 0% (0/52) | 1.8% (1/55)^§^
Mortality (cardiovascular) >30 days | Paroxysmal (2^nd^ line) | Wilber 2010^47^ | 12 months | 1.0% (1/103)^**^ | 0% (0/56)
Mortality (cardiovascular) >30 days | Persistent (1^st^/2^nd^ line) | Jones 2013^39^ (Heart failure) | 12 months | 3.8% (1/26)^††^ | 0% (0/26)
Mortality (cardiovascular) >30 days | Persistent (2^nd^ line) | Mont 2014^41^ | 12 months | 0% (0/98) | 0% (0/48)
Stroke (any type) >30 days | Paroxysmal (1^st^ line) | Wazni 2005^46^ | 12 months | 0% (0/32) | 0% (0/35)
Stroke (any type) >30 days | Paroxysmal (1^st^ line) | Morillo 2014^42^ | 24 months | 0% (0/66) | 0% (0/61)
Stroke (any type) >30 days | Persistent (2^nd^ line) | Mont 2014^41^ | 12 months | 0% (0/98) | 0% (0/48)
Stroke (any type) >30 days | Mixed (2^nd^ line) | Forleo 2009 (Diabetes) | 12 months | 0% (0/35) | 0% (0/35)
Myocardial infarction >30 days | Paroxysmal (1^st^ line) | Cosedis Nielsen 2012^35^ | 24 months | 0% (0/146) | 0.7% (1/148)
Transient ischemic attack >30 days | Paroxysmal (1^st^ line) | Wazni 2005^46^ | 12 months | 0% (0/32) | 0% (0/35)
Transient ischemic attack >30 days | Paroxysmal (1^st^ line) | Cosedis Nielsen 2012^35^ | 24 months | 0.7% (1/146) | 0.7% (1/148)
Transient ischemic attack >30 days | Paroxysmal (2^nd^ line) | Pappone 2011^83^ | 48 months | 0% (0/99) | 0% (0/99)
Transient ischemic attack >30 days | Persistent (2^nd^ line) | Mont 2014^41^ | 12 months | 0% (0/98) | 0% (0/48)
Transient ischemic attack >30 days | Mixed (2^nd^ line) | Forleo 2009^36^ (Diabetes) | 12 months | 0% (0/35) | 0% (0/35)
Transient ischemic attack >30 days | Mixed (2^nd^ line) | Stabile 2006^45^ | 12 months^‡‡^ | 0% (0/68) | 1.4% (1/69)
Intracranial hemorrhage | Persistent (1^st^/2^nd^ line) | Hunter 2014^37^ | 6 months | 0% (0/26) | 4.2% (1/24)
Congestive heart failure | Paroxysmal (1^st^ line) | Cosedis Nielsen 2012^35^ | 24 months | 0% (0/146) | 1.4% (2/148)
Progression from paroxysmal to persistent AF | Paroxysmal (2^nd^ line) | Pappone 2011^83^ | 48 months | 1.0% (1/99) | 19.2% (19/99)

AF = atrial fibrillation; CI = confidence interval; RCT = randomized controlled trial; RFA = radiofrequency ablation; RR = risk ratio.

* A meta-analysis was performed on the outcomes all-cause mortality >30 days and MI >30 days in RCTs with followup of ≤12 months (see Figure 3).

† Mortality, stroke, transient ischemic attack, and congestive heart failure all had to occur at a time point >30 days (or timing NR) to be considered an efficacy outcome.

‡ Mortality (all-cause): In the ablation group, 138 patients completed 24 month followup – the 2 patients with all-cause death (1 prostate cancer, 1 sudden death, cause unknown) were included in the loss-to-followup and have been added back into the denominator; in the medical therapy group, 137 patients completed 24 month followup – the 4 patients with all-cause death (2 lung cancer, 1 MI, 1 sudden death, cause unknown) were included in the loss-to-followup and have been added back into the denominator. Mortality (cardiovascular): 137 patients completed 24 month followup; the 1 patient with cardiovascular death (due to MI) was included in loss-to-follow and has been added back into the denominator for this outcome (also included under the outcome MI >30 days).

§ MI deemed not related to AADs. Also included under the outcome MI >30 days.

** 284 days postprocedure; acute MI deemed unrelated to ablation procedure. Also included under the outcome MI >30 days.

†† Patient with chronic lung disease, dilated cardiomyopathy, and a biventricular pacemaker.

‡‡ Followup time included a 1-month blanking period, for a total of 13 months followup.

Table 9 Primary effectiveness outcomes for comparative observational studies comparing RFA with medical therapy

Outcome^*^ | AF Type^†^ | Study^‡^ | Followup | RFA % (n/N) | Medical Therapy % (n/N) | p-value
Mortality (all-cause) >30 days | Persistent | Blandino 2013^48^ | Mean 60 months | 1.3% (2/153)^§^ | 1.9% (5/259)^§^ | 0.71
Mortality (all-cause) >30 days | Mixed | Sonne 2009^53^ | Mean 69 months | 2.1% (3/146)^§^ | 16.5% (34/205) | 0.01
Mortality (all-cause) >30 days | Mixed | Rossillo 2008^51^ | Mean 16 months | 0% (0/85) | 1.2% (1/85)^**^ | NR
Mortality (cardiovascular) >30 days | Persistent | Blandino 2013^48^ | Mean 60 months | 1.3% (2/153) | 1.9% (5/259) | 0.71
Mortality (cardiovascular) >30 days | Mixed | Sonne 2009^53^ | Mean 69 months | 2.1% (3/146) | 9.8% (20/205) | 0.0003^††^
Stroke (any type) >30 days | Mixed | Sonne 2009^53^ | Mean 69 months | 0% (0/146) | 1.5% (3/205) | NR
Stroke (any type) >30 days | Mixed | Rossillo 2008^51^ | Mean 16 months | 0% (0/85) | 4.7% (4/85) | NR
Stroke/TIA >30 days | Persistent | Blandino 2013^48^ | Mean 60 months | 1.3% (2/153) | 1.9% (5/259) | 0.71
Stroke/TIA >30 days | Mixed | Reynolds 2012^50^ | Mean 27 months | Annualized rate^‡‡^: 3.4% Kaplan-Meier estimate^§§^: 8.3% | Annualized rate^‡‡^: 5.5% Kaplan-Meier estimate^§§^: 14.1% | 0.005 HR: 0.62 95% CI (0.44-0.86)^***^
Myocardial infarction >30 days | Persistent | Blandino 2013^48^ | Mean 60 months | 0% (0/153) | 0.4% (1/259) | 1.0
Myocardial infarction >30 days | Mixed | Sonne 2009^53^ | Mean 69 months | 1.4% (2/146) | 0% (0/205) | NR
Thromboembolic events >30 days | Paroxysmal | Sang 2013^52^ | 12 months | 0% (0/82) | 3.6% (3/84) | NR
Peripheral embolism >30 days | Persistent | Blandino 2013^48^ | Mean 60 months | 0.6% (1/153) | 0.4% (1/259) | 1.0
Congestive heart failure | Persistent | Blandino 2013^48^ | Mean 60 months | 0% (0/153) | 1.2% (3/259) | 0.30
Congestive heart failure | Mixed | Sonne 2009^53^ | Mean 69 months | 0.7% (1/146) | 9.8% (20/205) | 0.002^††^
Hospitalization for heart failure | Mixed | Reynolds 2012^50^ | Mean 27 months | Annualized rate^‡‡^: 1.5% Kaplan-Meier estimate^§§^: 4.5% | Annualized rate^‡‡^: 2.2% Kaplan-Meier estimate^§§^: 5.5% | 0.155 HR: 0.69 95% CI (0.42-1.15)^***^

AF = atrial fibrillation; NA = not applicable; NR = not reported; RFA = radiofrequency ablation; TIA = transient ischemic attack.

* Mortality, stroke, TIA, MI, and embolic events all had to occur at a time point >30 days (or timing NR) to be considered an effectiveness outcome. Stroke, TIA, thromboembolic events and peripheral embolism were not defined further in their respective studies.

† All treatments were a second-line therapy for AF.

‡ Blandino 2013 and Sonne 2009 represent the Medicare population (age ≥75 years and mean age 67 years, respectively); all other studies represent the general adult population. Also regarding Sonne 2009, only results from the group that underwent pulmonary vein antrum isolation are reported (the authors also included a group who underwent atrioventricular junction ablation which is an intervention excluded from our report).

§ All cardiovascular-related.

** Cause of death was stroke. This patient is also counted under stroke (any type).

†† Based on t-test calculated by the EPC.

‡‡ Annualized rate calculated as percentage (number of patients in the cohort who had an event within 3 years/average length of followup in the cohort). TIA indicates transient ischemic attack.

§§ Product-limit estimates of the 3-year event rates (percentages) and P values of the nonparametric log-rank test comparing survival functions of the 2 cohorts.

*** Unadjusted Cox regression estimate of the hazard ratio for models with cohort as the only predictor variable and the Wald chi squared p value for significance of cohort.

###### Health-Related Quality of Life

A variety of HRQOL measures were used at varied time frames across trials, which, combined with clinical heterogeneity across studies, limited this review’s ability to pool data or draw firm conclusions regarding the HRQOL outcome. Further, trial sizes may have been insufficient to detect significant differences between treatments for most measures. The SF-36 was the most frequently used questionnaire, with eight trials reporting outcomes for at least one subscale. The MLHFQ was the second most commonly used HRQOL measure, with three trials in people with persistent AF and CHF reporting.

SF-36. Eight fair-quality trials comparing RFA with medical therapy in patients with paroxysmal AF reported SF-36 results but did so in a variety of ways across different time frames which limited the ability to pool results (Tables 10, 11, 12, and 14).35, 36, 38, 46, 47, 83 40 Five reported both the MCS and PCS.35, 38, 40, 47, 83 Individual SF-36 domains were reported by five trials, including two of those that reported MCS and PCS scores.36–38, 46, 83 Results are presented based on intention-to-treat analysis; however, substantial crossover from medical therapy to RFA in most studies (crossover frequency 37% to 88%) should be considered when interpreting these results.

Four of the five trials reporting the SF-36 MCS and PCS were in patients with paroxysmal AF;35, 38, 47, 83 the fifth trial was in persistent AF patients with heart failure.40 One trial in paroxysmal AF patients used RFA as a first line treatment and was the only trial to provide data on both short and long-term followup.35

One trial of paroxysmal AF patients reported that RFA patients saw greater improvements at 3 months in SF-36 MCS and PCS outcomes than did those who received medical therapy, however this time frame is likely too soon after the procedure (i.e., during post-procedure healing) to be an accurate reflection of quality of life.47 Across the remaining three trials of paroxysmal AF patients, data were reported between 12 and 48 months. For the MCS, only one of three found statistically greater improvement following RFA versus medical therapy38; for the PCS, two of three reported significant results that favored RFA.35, 38 The one trial of persistent AF patients with heart failure showed that quality of life tended to be better at 6 months following RFA than medical therapy, although the results were only statistically significant for the PCS (Table 10).40

Pooled analysis was possible across two fair-quality trials comparing RFA with medical therapy in patients with paroxysmal AF.35, 38 These studies contained sufficient data on the SF-36 MCS and PCS at 12 months based on intention-to-treat analyses (Table 11). No statistical differences between treatment groups were observed for the SF-36 MCS at 12 months; this held true whether the analysis was done using the mean scores at followup or using the change from baseline scores. In terms of individual study results, neither study reported an effect based on change from baseline scores, but the smaller study38 found a significant effect favoring RFA based on followup scores only. For PCS, RFA was favored over medical therapy when the pooled estimate was calculated using differences in mean followup scores (overall effect 2.85; 95% CI 0.93 to 4.82; I^2^=0%), however when the analysis was based on the change from baseline the effect was no longer statistically meaningful (overall effect 2.88; 95% CI 0.18 to 5.25, I^2^ =32.89%). Individual study data suggested that quality of life based on SF-36 scores may be significantly better following RFA than medical therapy, although the smaller study38 showed no treatment effect in one analysis. Because these results are only based on two studies, and because one trial employed catheter ablation as a first line therapy while the other used the treatment as a second line therapy, it is difficult to arrive at firm conclusions regarding this outcome. No difference between treatments in baseline scores were seen in either study. Although the timing of cross-over for the two pooled studies is unclear, it appears that the average timing of cross over may have been around 6 months in both studies.

A followup report to the Wilber trial reported HRQOL outcomes at six and twelve months, but data were not analyzed based on intention to treat (the 65% [31/48] of AAD patients who crossed over and received ablation were excluded from the analysis).84 Based on this analysis, authors reported that QOL outcomes were significantly better in those randomized to RFA than those who received only medical therapy at both six and twelve months.

Outcomes from additional SF-36 domains were reported in five trials,36–38, 46, 83 though one of these trials did not provide any data (Table 12).38 Three trials reported on patients with paroxysmal AF. While one trial reported statistical differences favoring RFA were noted for most domains (physical functioning, role physical, bodily pain, general health, social functioning) at 6 months,46 a second trial found no differences between treatments at 48 months for any domain.83 A third trial reported statistically greater improvements following RFA vs. medical therapy for six of the eight domains, however no other information (i.e., which domains improved, timing of the evaluation, data) was provided.38 One trial in diabetic patients with either type of AF reported statistical differences in mean change between groups favoring RFA for some domains (physical functioning, bodily pain, general health, social functioning, and role emotional).36 One trial in persistent AF patients with concomitant CHF reported statistically significant improvement in four domains (physical functioning, role physical, bodily pain and vitality) at 6 months.37 Across the four clinically heterogeneous trials that provided data at discrepant time frames, bodily pain was significantly better in the RFA groups in three of the four trials.36, 37, 46 Two heterogeneous trials reported greater improvement in RFA patients in the role physical domain, and two reported improvement in the general health domain.

Three comparative observational studies reported SF-36 outcomes (Table 13).48, 52, 54 Two studies were on paroxysmal patients. The fair-quality study of paroxysmal AF patients found that the SF-36 PCS and MCS scores increased significantly more 12 months following ablation compared with medical therapy).52 A poor-quality study in these patients reported that the total SF-36 score increased in the ablation group after 12 months but not in the medical therapy group.54 Authors do not report whether there was a significant difference between groups for total score or individual domain scores and there were significant differences between groups at baseline. A fair-quality study of elderly (≥75 years) persistent AF patients showed statistically meaningful improvements in all SF-36 domain scores (except bodily pain) between groups over a mean followup period of 60 months; again substantial differences at baseline between groups for most domains were noted.48 The limitations of these studies should be considered in interpreting these findings. Individual SF-36 domain scores for the comparative observational studies can be found in Table H3 of the Appendix.

Minnesota Living with Heart Failure Questionnaire. The MLHFQ was reported in three trials, all of which were in patients with persistent AF and concomitant heart failure (Table 14).37, 39, 40

All three trials evaluated patients at 6 months. Two of the trials reported statistically significant differences favoring RFA at 6 months (Hunter: 23.7 versus 47.0, p=0.001; Jones: data not reported, p=0.02),37, 39 while the third trial tended to favor RFA, results did not reach statistical difference (change from baseline −5.7 ± 19.7 for RFA vs. −2.8 ± 17.9).40 One trial reported that the significantly greater improvement seen 6 months after RFA versus medical therapy found a similar effect at 12 months (mean 21 ± 19 for RFA vs. 41 ± 21, p=0.02).39

Other quality-of-life measures. A variety of other HRQOL measures were used at varied time frames across studies (Table 14). Again, small trial sizes and substantial crossover from medical therapy to RFA should be considered; these factors, along with the variety of measures used across studies make it difficult to draw firm conclusions.

In patients with paroxysmal AF, no differences between treatment groups in EQ-5D were observed at 12 months in one trial.42 In patients with persistent AF (and heart failure), one trial found no differences between treatment groups in Kansas City Cardiomyopathy (KCCQ) scores,40 while a difference favoring RFA in the New York Heart Association (NYHA) score at 6 months was seen in another.37 An additional analysis of the Mont SARA trial reported and found that there were significant improvements at 12 months in the Atrial Fibrillation Quality of Life Questionnaire (AFQOL) scores in the RFA but not medical therapy group, however their methods don’t allow for direct comparisons between treatment groups, precluding firm conclusions.41, 85

Two nonrandomized comparative studies, one fair- and the other poor-quality, assessed the Self-Rating Depression Scale (SDS) and the Self-Rating Anxiety Scale (SAS) at 12 months in patients with paroxysmal AF.52, 54 Both studies reported a significant improvement compared with baseline in mean SDS and SAS scores following RFA (Table 13), although limitations in the way the outcomes limit the ability to draw conclusions.

There were insufficient data to formally compare HRQOL for those receiving RFA as a first-line versus second-line therapy, however no consistent patterns of improvement in QOL are seen across studies. For RFA as first-line treatment, two trials in those with paroxysmal AF employed the SF-36.^35, 46^ At 6 months, one reported significant improvement in individual domains (physical function, role physical, bodily pain, general health and social function).46 The other found that the PCS was significantly improved favoring RFA at 12 months, but not at 24 months and MCS was not significant at either time. Two other trials of RFA as a first-line treatment reported no difference in EQ5D assessments in those with paroxysmal AF42 or in AF-QOL domains in those with persistent AF.41 For RFA as a second-line treatment, SF-36 there were no significant differences in SF-36 domains or in MCS or PCS at 48 months in one trial of paroxysmal AF patients83 and another in heart failure patients with persistent AF reported no difference at 6 months in MCS, but PCS favored RFA (Table 10).40 Another trial reported that six of the eight SF-36 domains favored RFA but didn’t provide data or information on measurement timing (Table 12).38

Symptom improvement. Across the two trials (both in paroxysmal AF) using the Symptom Checklist, one reported no difference between treatment groups at 3 months in the Frequency Scale or the Severity Scale,38 while the other study reported a significant decrease in both scales in the RFA group compared with the medical group (Table 14). 47 At 12 months, there was no difference in the Frequency Scale but a difference favoring RFA in the Severity Scale in the only study reporting this length of followup.38

Table 10 SF-36 MCS and PCS scores from RCTs comparing RFA with medical therapy^*^

META-ANALYSIS – SF-36 (see Table 11)
Outcome^†^ | AF Type (1^st^/2^nd^ line therapy) and Study | Followup | RFA | Medical Therapy | p-value
SF-36 MCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (1^st^ line), Cosedis Nielsen 2012^35^ | Baseline | 45.2 ± 11.7 (n=146) | 46.1 ± 11.2 (n=148) | 0.50^‡^
SF-36 MCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (1^st^ line), Cosedis Nielsen 2012^35^ | 12 months | 50.8 ± 9.3 (n=146) | 50.1 ± 8.5 (n=148) | 0.70^‡^
SF-36 MCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (1^st^ line), Cosedis Nielsen 2012^35^ | 24 months | 51.1 ± 9.2 (n=146) | 50.9 ± 8.0 (n=148) | 0.93^§^
SF-36 MCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 46.1 (n=53) | 44.0 (n=59) | NS
SF-36 MCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 56.6 ± 7.8 (n=53) | 51.9 ± 9.7 (n=59) | .01
SF-36 MCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (2^nd^ line), Wilber 2010^47^ | Baseline | 44.5 (42.2–46.7) (n=97) | 44.0 (40.7–−47.3) (n=53) | 0.79
SF-36 MCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (2^nd^ line), Wilber 2010^47^ | 3 month change | +8.5 (5.9–11.1) (n=90) | +1.6 (−1.1 to 4.3) (n=39) | <0.001
SF-36 MCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (2^nd^ line), Pappone 2011^83^ | Baseline | 43.7 ± 11 (n=99) | 44.4 ± 10 (n=99) | 0.64^‡^
SF-36 MCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (2^nd^ line), Pappone 2011^83^ | 48 months | 52.9 ± 9 (n=99) | 51.9 ± 9 (n=99) | 0.44^‡^
SF-36 MCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | Baseline | 40.7 ± 10.2 (n=20) | 37.1 ± 14.0 (n=18) | 0.37^‡^
SF-36 MCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | 6 month change | +0.4 ± 9.5 (n=20) | +5.9 ± 8.5 (n=18) | 0.07
SF-36 PCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (1^st^ line), Cosedis Nielsen 2012^35^ | Baseline | 44.3 ± 8.9 (n=146) | 45.2 ± 8.9 (n=148) | 0.39
SF-36 PCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (1^st^ line), Cosedis Nielsen 2012^35^ | 12 months | 50.2 ± 8.5 (n=146) | 47.5 ± 9.7 (n=148) | 0.01^‡^
SF-36 PCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (1^st^ line), Cosedis Nielsen 2012^35^ | 24 months | 50.0 ± 8.8 (n=146) | 47.9 ± 8.9 (n=148) | 0.23^§^
SF-36 PCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 44.8 (n=53) | 43.0 (n=59) | NS
SF-36 PCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 52.0 ± 7.6 (n=53) | 48.9 ± 7.2 (n=59) | .01
SF-36 PCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (2^nd^ line), Wilber 2010^47^ | Baseline | 46.1 (44.4–47.8) (n=97) | 47.6 (45.3–50.0) (n=53) | 0.29
SF-36 PCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Paroxysmal (2^nd^ line), Wilber 2010^47^ | 3 month change | +6.9 (5.2–8.6) (n=90) | +0.4 (−1.7 to 2.6) (n=39) | <0.001
SF-36 PCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | 11Paroxysmal (2^nd^ line), Pappone 2011^83^ | Baseline | 44.4 ± 9 (n=99) | 45.7 ± 9 (n=99) | 0.31^‡^
SF-36 PCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | 11Paroxysmal (2^nd^ line), Pappone 2011^83^ | 48 months | 52.3 ± 9 (n=99) | 52.6 ± 8 (n=99) | 0.80^‡^
SF-36 PCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | Baseline | 30.3 ± 9.2 (n=20) | 30.3 ± 7.1 (n=18) | 1.00^‡^
SF-36 PCS, mean ± SD (95% CI) [score range 0 (worst) to 100 (best)] | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | 6 month change | +4.0 ± 9.5 (n=20) | −1.0 ± 4.4 (n=18) | 0.04

AF = atrial fibrillation; CI = confidence interval; MCS = Mental Component Score; PCS = Physical Component Score; NR = not reported; NS = not significant; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation; SD = standard deviation; SF-36 = Short Form-36 Questionnaire.

* A meta-analysis was performed for the SF-36 MCS and PCS from RCTs of paroxysmal AF patients with followup of ≤12 months (see Table 11).

† A higher score reflects better health status.

‡ Based on t-test calculated by the EPC.

§ p-value for the effect of group, time, and interaction between time and group from a repeated-measures analysis of variance as reported by authors.

Table 11 Meta-analysis results for the SF-36 MCS and PCS at 12-months followup from RCTs comparing RFA with medical therapy in patients with paroxysmal AF

Outcome | | RFA (N) | Medical (N) | Effect Size (95% CI)^*^ | Weight | Heterogeneity (I^2^)
SF-36 MCS | Difference in change scores: Cosedis Nielsen 2012^35^ (1^st^ line) | 146 | 148 | 1.60 (−0.78, 3.98) | 71.72%
SF-36 MCS | Difference in change scores: Jais 2008^38^ (2^nd^ line) | 53 | 59 | 2.60 (−1.19, 6.39) | 28.28%
SF-36 MCS | Pooled difference in change scores | 199 | 207 | 1.88 (−0.47, 4.50) | 100.00% | 0.00%
SF-36 MCS | Difference in mean scores at followup: Cosedis Nielsen 2012^35^ (1^st^ line) | 146 | 148 | 0.70 (−1.34, 2.74) | 60.91%
SF-36 MCS | Difference in mean scores at followup: Jais 2008^38^ (2^nd^ line) | 53 | 59 | 4.70 (1.45, 7.95) | 39.09%
SF-36 MCS | Pooled difference in mean scores | 199 | 207 | 2.26 (−2.12, 7.40) | 100.00% | 49.82%
SF-36 PCS | Difference in change scores: Cosedis Nielsen 2012^35^ (1^st^ line) | 146 | 148 | 3.60 (1.54, 5.66) | 68.82%
SF-36 PCS | Difference in change scores: Jais 2008^38^ (2^nd^ line) | 53 | 59 | 1.30 (−1.76, 4.36) | 31.18%
SF-36 PCS | Pooled difference in change scores | 199 | 207 | 2.88 (−0.18, 5.25) | 100.00% | 32.89%
SF-36 PCS | Difference in mean scores at followup: Cosedis Nielsen 2012^35^ (1^st^ line) | 146 | 148 | 2.70 (0.62, 4.78) | 63.52%
SF-36 PCS | Difference in mean scores at followup: Jais 2008^38^ (2^nd^ line) | 53 | 59 | 3.10 (0.35, 5.85) | 36.48%
SF-36 PCS | Pooled difference in mean scores | 199 | 207 | 2.85 (0.93, 4.82) | 100.00% | 0.00%

AF = atrial fibrillation; CI = confidence interval; MCS = Mental Component Score; PCS = Physical Component Score; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation; SF-36 = Short-Form 36 questionnaire.

* Profiled Likelihood method.

Table 12 Individual SF-36 domain scores from RCTs comparing RFA with medical therapy

SF-36 Domain | Wazni 2005 (N=67)46 Paroxysmal AF First line 6 months RFA vs. Med; p-value (means) | Pappone 2011 (n=198)83 Paroxysmal Second line 48 months RFA vs. Med; p-value (means) | Forleo 2009 (n=70)36 Mixed population Diabetic patients Second line 12 months RFA vs. Med; p-value (difference in mean change between groups) | Hunter 2014 (n=50)37 Persistent AF Heart failure patients First/second line 6 months RFA vs. Med; p-value (score reported as %)
Physical Functioning | 97 vs. 75; p=0.001 | 85 vs. 82; p=0.122^†^ | 8.4^‡^; p<0.05 | 71% vs. 49.1%; p=0.007
Role Physical | 71 vs. 53; p=0.047 | 82 vs. 80; p=0.333^†^ | NR; NS | 67.5% vs. 42.4%; p=0.004
Bodily Pain | 97 vs. 90; p=0004 | 80 vs. 77; p=0.271^†^ | 5.9^‡^; p<0.05 | 78.8% vs. 57.1%; p=0.005
General Health | NR^*^ vs. 68; p<0.001 | 79 vs. 77; p=0.365^†^ | 8.9^‡^; p<0.05 | NR; NS
Vitality | 65 vs. 60; p=0.21 | 71 vs. 68; p=0.339^†^ | NR; NS | 54.3% vs. 36.4%; p=0.009
Social Functioning | 93 vs. 82; p=0.004 | 87 vs. 86; p=0.616^†^ | 7.7^‡^; p<0.05 | NR: NS
Role Emotional | 76 vs. 75; p=0.90 | 86 vs. 84; p=0.448^†^ | 6.8^‡^; p<0.05 | NR; NS
Mental Health | 65 vs. 68; p=0.62 | 81 vs. 78; p=0.216^†^ | NR; NS | NR; NS

AF = atrial fibrillation; Med = medical therapy; NR = not reported; NS = not statistically significant; RCT = randomized controlled trial; RFA = radiofrequency ablation; SF-36 = Short Form 36 Questionnaire.

* Authors report this value as 9 ± 1; however, this appears to be a typo in the article and the correct value cannot be ascertained. The authors report that the improvement in quality of life of patients in the ablation group was significantly better than the improvement in quality of life in the medical group.

† Based on t-test calculated by EPC (authors did not report p-values).

‡ Difference in mean change of quality of life scores between groups. Favored RFA.

Table 13 Quality of life outcomes for comparative observational studies comparing RFA with medical therapy

Outcome | AF Type^*^ and Study | Followup | RFA | Medical Therapy | p-value
SF-36 MCS [score range 0 (worst) to 100 (best)] | Paroxysmal, Sang 2013^52^ | Baseline | 42.2 ± 7.2 (n=82) | 43.2 ± 7.2 (n=84) | 0.36
SF-36 MCS [score range 0 (worst) to 100 (best)] | Paroxysmal, Sang 2013^52^ | 12 months | 54.6 (n=82) | 43.9 (n=84) | <0.001
SF-36 PCS [score range 0 (worst) to 100 (best)] | Paroxysmal, Sang 2013^52^ | Baseline | 42.6 ± 6.4 (n=82) | 43.0 ± 6.2 (n=84) | .68
SF-36 PCS [score range 0 (worst) to 100 (best)] | Paroxysmal, Sang 2013^52^ | 12 months | 52.9 (n=82) | 43.4 (n=84) | <0.001
Total SF-36 Score | Paroxysmal, Yu 2012^54^ | Baseline | 565.29 ± 143.37 (n=97) | 525.24 ± 143.60 (n=102) | NR
Total SF-36 Score | Paroxysmal, Yu 2012^54^ | 12 months | 606.84 ± 102.84 (n=97) | 545.25 ± 103.68 (n=102) | NR
Zung Self-Rating Anxiety Scale [score range 20 (best) to 80 (worst)] | Paroxysmal, Sang 2013^52^ | Baseline | 48.6 ± 11.1 (n=82) | 47.7 ± 10.3 (n=84) | .59
Zung Self-Rating Anxiety Scale [score range 20 (best) to 80 (worst)] | Paroxysmal, Sang 2013^52^ | 12 months | NR (n=84) | NR (n=84) | <0.001^‡^
Zung Self-Rating Anxiety Scale [score range 20 (best) to 80 (worst)] | Paroxysmal, Yu 2012^54^ | Baseline | 41.69 ± 8.32^§^ (n=97) | 44.88 ± 6.98^§^ (n=102) | NR
Zung Self-Rating Anxiety Scale [score range 20 (best) to 80 (worst)] | Paroxysmal, Yu 2012^54^ | 12 months | 37.66 ± 4.82^§^ (n=97) | 43.89 ± 5.64^§^ (n=102) | <0.001
Zung Self-Rating Depression Scale [score range 20 (best) to 80 (worst)] | Paroxysmal, Sang 2013^52^ | Baseline | 49.4 ± 10.6 (n=82) | 48.7 ± 10.8 (n=84) | .71
Zung Self-Rating Depression Scale [score range 20 (best) to 80 (worst)] | Paroxysmal, Sang 2013^52^ | 12 months | NR (n=84) | NR (n=84) | <0.001^‡^
Zung Self-Rating Depression Scale [score range 20 (best) to 80 (worst)] | Paroxysmal, Yu 2012^54^ | Baseline | 45.01 ± 9.71^§^ (n=97) | 50.18 ± 9.07^§^ (n=102) | NR
Zung Self-Rating Depression Scale [score range 20 (best) to 80 (worst)] | Paroxysmal, Yu 2012^54^ | 12 months | 40.05 ± 8.56^§^ (n=97) | 49.63 ± 9.12^§^ (n=102) | <0.001

AF = atrial fibrillation; MCS = Mental Component Score; NR = not reported; PCS = Physical Component Score; RFA = radiofrequency catheter ablation; SF-36: Short-Form-36.

* All treatments were a second-line therapy for AF.

† Blandino et al. 2013 is a Medicare population (age ≥75 years). All other studies represent the general adult population.

‡ 12 months after ablation, mean SAS and SDS scores were significantly decreased compared with baseline scores in the ablation but not the medical group; catheter ablation achieved a better intervention effect than AAD therapy (F = 35.60, p<0.001 for SAS; F = 31.56, p<0.001 for SDS).

§ Normalized scores (total score multiplied by 1.25).

Table 14 Other health-related quality of life and symptom checklist outcomes from RCTs comparing RFA with medical therapy

Outcome^*^ | AF Type (1^st^/2^nd^ line therapy) and Study | Followup | RFA | Medical Therapy | p-value
MLHFQ, mean ± SD (95% CI) [Score range: 0 (best) to 105 (worst)] | Persistent (1^st^/2^nd^ line), Jones39 (heart failure) | Baseline | 42 ± 23 (n=26) | 49 ± 21 (n=26) | 0.23
MLHFQ, mean ± SD (95% CI) [Score range: 0 (best) to 105 (worst)] | Persistent (1^st^/2^nd^ line), Jones39 (heart failure) | 3 months | NR (n=26) | NR (n=26) | 0.20
MLHFQ, mean ± SD (95% CI) [Score range: 0 (best) to 105 (worst)] | Persistent (1^st^/2^nd^ line), Jones39 (heart failure) | 6 months | NR (n=26) | NR (n=26) | 0.02
MLHFQ, mean ± SD (95% CI) [Score range: 0 (best) to 105 (worst)] | Persistent (1^st^/2^nd^ line), Jones39 (heart failure) | 12 months | 21 ± 19 (n=26) | 41 ± 21 (n=26) | 0.02
MLHFQ, mean ± SD (95% CI) [Score range: 0 (best) to 105 (worst)] | Persistent (2nd line), MacDonald 2011^40^ (heart failure) | Baseline | 55.8 ± 19.8 (n=22) | 59.2 ± 22.4 (n=19) | NR
MLHFQ, mean ± SD (95% CI) [Score range: 0 (best) to 105 (worst)] | Persistent (2nd line), MacDonald 2011^40^ (heart failure) | 6 month change | −5.7 ± 19.7 (n=22) | −2.8 ± 17.9 (n=19) | 0.65
MLHFQ, mean ± SD (95% CI) [Score range: 0 (best) to 105 (worst)] | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | Baseline | 42^‡^ (n=26) | 47^‡^ (n=24) | NR
MLHFQ, mean ± SD (95% CI) [Score range: 0 (best) to 105 (worst)] | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | 6 months | 23.7 (14.6 to 32.8) (n=25) | 47.0 (36.5 to 57.6) (n=23) | 0.001
MLHFQ, mean ± SD (95% CI) [Score range: 0 (best) to 105 (worst)] | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | 12 months | 26.5 (16.9 to 36.2) (n=25) | NR | NA
AF-QOL Global Score,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | Baseline | 42.0 (n=98) | 49.3 (n=48) | NR
AF-QOL Global Score,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | 6 months | 53.7 (n=98) | 48.2 (n=48) | 0.16
AF-QOL Global Score,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | 12 months | 56.8 (n=98) | 53.0 (n=48) | 0.41
AF-QOL Psychological Domain,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | Baseline | 34.8 (n=98) | 45.7 (n=48) | NR
AF-QOL Psychological Domain,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | 6 months | 51.8 (n=98) | 44.2 (n=48) | 0.08
AF-QOL Psychological Domain,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | 12 months | 54.8 (n=98) | 48.9 (n=48) | 0.25
AF-QOL Physical Domain,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | Baseline | 44.1 (n=98) | 48.7 (n=48) | NR
AF-QOL Physical Domain,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | 6 months | 54.1 (n=98) | 49.7 (n=48) | 0.34
AF-QOL Physical Domain,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | 12 months | 56.2 (n=98) | 55.6 (n=48) | 0.91
AF-QOL Sexual Domain,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | Baseline | 53.9 (n=98) | 60.8 (n=48) | NR
AF-QOL Sexual Domain,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | 6 months | 57.0 (n=98) | 51.9 (n=48) | 0.34
AF-QOL Sexual Domain,^†^ mean [Score range: 0 (worst) to 100 (best)] | Persistent (1^st^ line), Mont 2014^41^ | 12 months | 63.7 (n=98) | 55.4 (n=48) | 0.12
EQ5D Tariff Score, median (IQR) [Score range: 0 (death) to 1 (optimal health)] | Paroxysmal (1^st^ line), Morillo 2014^42^ | Baseline | 0.86 (0.82–1) (n=66) | 0.84 (0.83–1) (n=61) | >0.99
EQ5D Tariff Score, median (IQR) [Score range: 0 (death) to 1 (optimal health)] | Paroxysmal (1^st^ line), Morillo 2014^42^ | 12 months | 1 (0.84–1) (n=66) | 1 (0.83–1) (n=61) | 0.25
EQ5D Anxiety/Depression (%) [Score range: 0 (death) to 1 (optimal health)] | Paroxysmal (1^st^ line), Morillo 2014^42^ | Baseline | 31.8% (n=66) | 26.2% (n=61) | 0.70
EQ5D Anxiety/Depression (%) [Score range: 0 (death) to 1 (optimal health)] | Paroxysmal (1^st^ line), Morillo 2014^42^ | 12 months | 13.6% (n=66) | 23% (n=61) | 0.25
EQ5D VAS, median (IQR) [Score range: 0 (worst) to 100 (best)] | Paroxysmal (1^st^ line), Morillo 2014^42^ | Baseline | 75 (70–83) (n=66) | 80 (70–85) (n=61) | 0.53
EQ5D VAS, median (IQR) [Score range: 0 (worst) to 100 (best)] | Paroxysmal (1^st^ line), Morillo 2014^42^ | 12 months | 85 (85–90) (n=66) | 80 (75–90) (n=61) | 0.26
KCCQ, mean ± SD [Score range: 0 (worst) to 100 (best)] | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | Baseline | 42.1 ± 16.5 (n=22) | 37.1 ± 19.5 (n=19) | NR
KCCQ, mean ± SD [Score range: 0 (worst) to 100 (best)] | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | 6 month change | +7.1 ± 21.1 (n=22) | +5.6 ± 14.0 (n=19) | 0.81
NYHA Score, mean (95% CI) [Score range: 1 (best) to 4 (worst) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | Baseline | 2.6^‡^ (n=26) | 2.5^‡^ (n=24) | NR
NYHA Score, mean (95% CI) [Score range: 1 (best) to 4 (worst) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | 6 months | 1.6 (1.4 to 1.9) (n=25) | 2.4 (2.1 to 2.6) (n=23) | <0.001
NYHA Score, mean (95% CI) [Score range: 1 (best) to 4 (worst) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | 12 months | 1.7 (1.4 to 2.0) (n=25) | NR | NA
Symptom Checklist Frequency Scale, mean (95% CI) [Score range: 0 (worst) to 64 (best)] | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 37.1 (n=53) | 35.9 (n=59) | NS
Symptom Checklist Frequency Scale, mean (95% CI) [Score range: 0 (worst) to 64 (best)] | Paroxysmal (2^nd^ line), Jais 2008^38^ | 3 months | 29.7 (n=53) | 33.0 (n=59) | NR
Symptom Checklist Frequency Scale, mean (95% CI) [Score range: 0 (worst) to 64 (best)] | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 26.8 (n=53) | 31.1 (n=59) | 0.10
Symptom Checklist Frequency Scale, mean (95% CI) [Score range: 0 (worst) to 64 (best)] | Paroxysmal (2^nd^ line), Wilber 2010^47^ | Baseline | 20.7 (18.9–22.6) (n=94) | 18.6 (16.2–21.1) (n=51) | 0.18
Symptom Checklist Frequency Scale, mean (95% CI) [Score range: 0 (worst) to 64 (best)] | Paroxysmal (2^nd^ line), Wilber 2010^47^ | 3 month change | −11.1 (−12.9 to −9.3) (n=94) | 0.7 (−2.4 to 3.9) (n=51) | <0.001
Symptom Checklist Severity Scale, mean (95% CI) [Score range: 0 (worst) to 48 (best)] | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 22.1 (n=53) | 21.5 (n=59) | NS
Symptom Checklist Severity Scale, mean (95% CI) [Score range: 0 (worst) to 48 (best)] | Paroxysmal (2^nd^ line), Jais 2008^38^ | 3 months | 12.0 (n=53) | 18.7 (n=59) | NR
Symptom Checklist Severity Scale, mean (95% CI) [Score range: 0 (worst) to 48 (best)] | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 10.4 (n=53) | 13.3 (n=59) | 0.001
Symptom Checklist Severity Scale, mean (95% CI) [Score range: 0 (worst) to 48 (best)] | Paroxysmal (2^nd^ line), Wilber 2010^47^ | Baseline | 17.1 (15.5–18.7) (n=76) | 16.0 (13.7–18.4) (n=44) | 0.44
Symptom Checklist Severity Scale, mean (95% CI) [Score range: 0 (worst) to 48 (best)] | Paroxysmal (2^nd^ line), Wilber 2010^47^ | 3 month change | −9.4 (−10.9 to −7.9) (n=76) | 0 (−3.3 to 3.4) (n=44) | <0.001

AF = atrial fibrillation; AF-QOL = Atrial Fibrillation Quality of Life Questionnaire; CI = confidence interval; EQ5D = European Quality of Life-5 Dimensions; IQR = interquartile range; KCCQ = Kansas City Cardiomyopathy Questionnaire; MLHFQ = Minnesota Living with Heart Failure Questionnaire; NR = not reported; NS = not significant; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation; SD = standard deviation.

* For all outcomes except the Minnesota Living with Heart Failure Questionnaire, a higher score reflects better health status.

† 6 and 12 month results reported as baseline-adjusted (least-squares) means.

‡ Baseline scores were estimated from the graphs provided.

###### Functional Outcomes

Three fair-quality trials evaluated the influence of treatment on aspects of exercise, one of which was in patients with paroxysmal AF which used RFA as a second-line therapy38 and two were in patients with heart failure who had persistent AF.39, 40

In the small trial in patients with paroxysmal AF,38 at 12 months maximum heart rate, maximum workload and total metabolic equivalents achieved were significantly higher in those receiving RFA, but there was no difference in exercise duration between treatments (Table 13).

Two small trials in patients who had heart failure in addition to persistent AF reported no differences in change from baseline on the 6-minute walk test between treatment groups at 6 months40 (mean +20.1 ± 76.5 for RFA vs. +21.4 ± 77.4 for medical therapy) at 12 months39 (median +21 [−51 to +89] vs. 10 [−73 to +15]) (Table 15). Mean peak VO_2_ consumption was statistically higher in the RFA group as reported by two trials, one at 6 months (22.4, 95% CI 19.7 to 25.1 vs. 17.7, 95% CI 15.0 to 20.4)37 and one at 12 months (18.7 ± 7.5 vs. 17.3 ± 5.4)39; both studies were in people with persistent AF and concomitant heart failure.

Of the seven included observational studies, none assessed functional outcomes.

Table 15 Exercise capacity and related outcomes from randomized controlled trials comparing radiofrequency ablation with medical therapy

Outcome | AF Type (1^st^/2^nd^ line therapy) and Study | Followup | RFA | Medical Therapy | p-value
6-minute walk test (meters), mean ± SD, median (IQR) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | Baseline | 416 ± 78 (n=26) | 411 ± 109 (n=26) | 0.84
6-minute walk test (meters), mean ± SD, median (IQR) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | 12 month change | +21 (−51 to +89) (n=26) | −10 (−73 to +15) (n=26) | 0.095
6-minute walk test (meters), mean ± SD, median (IQR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | Baseline | 317.5 ± 125.8 (n=17) | 351.8 ± 117.1 (n=15) | NR
6-minute walk test (meters), mean ± SD, median (IQR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | 6 month change | +20.1 ± 76.5 n=17) | +21.4 ± 77.4 n=15) | 0.96
Stress tests, mean ± SD Exercise duration (minutes) | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 9.5 ± 4.0 (n=53) | 9.1 ± 4.1 (n=59) | NS
Stress tests, mean ± SD Exercise duration (minutes) | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 12.4 ± 5.3 (n=53) | 10.3 ± 4.6 (n=59) | 0.17
Stress tests, mean ± SD Heart rate at rest (bpm) | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 81.0 ± 26.4 (n=53) | 73.1 ± 21.4 (n=59) | NS
Stress tests, mean ± SD Heart rate at rest (bpm) | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 82.0 ± 20.5 n=53) | 74.0 ± 13.9 (n=59) | 0.002
Stress tests, mean ± SD Maximum heart rate (bpm) | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 150.2 ± 25.9 (n=53) | 140.1 ± 28.3 (n=59) | NS
Stress tests, mean ± SD Maximum heart rate (bpm) | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 154.8 ± 18.3 (n=53) | 139.2 ± 23.9 (n=59) | 0.01
Stress tests, mean ± SD Maximum workload (W) | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 157.8 ± 56.3 (n=53) | 176.1 ± 61.8 (n=59) | NS
Stress tests, mean ± SD Maximum workload (W) | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 187.6 ± 54.4 (n=53) | 163.2 ± 49.9 (n=59) | 0.02
Stress tests, mean ± SD METS | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 8.4 ± 2.6 (n=53) | 8.0 ± 2.7 (n=59) | NS
Stress tests, mean ± SD METS | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 9.5 ± 2.3 (n=53) | 8.1 ± 2.6 (n=59) | 0.002
Peak VO_2_ consumption (ml/kg/min), mean ± SD (95% CI) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | Baseline | 16.3 ± 5.3 (n=26) | 18.2 ± 4.8 (n=26) | 0.19
Peak VO_2_ consumption (ml/kg/min), mean ± SD (95% CI) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | 3 months | 17.1 ± 5.4 (n=26) | 18.0 ± 4.6 (n=26) | 0.38
Peak VO_2_ consumption (ml/kg/min), mean ± SD (95% CI) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | 12 months | 18.7 ± 7.5 (n=26) | 17.3 ± 5.4 (n=26) | 0.02
Peak VO_2_ consumption (ml/kg/min), mean ± SD (95% CI) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | Baseline | 21.5^*^ | 19.5^*^ | NR
Peak VO_2_ consumption (ml/kg/min), mean ± SD (95% CI) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | 6 months | 22.4 (19.7 to 25.1) (n=25) | 17.7 (15.0 to 20.4) (n=23) | 0.01
Peak VO_2_ consumption (ml/kg/min), mean ± SD (95% CI) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | 12 months | 21.5 (18.8 to 24.3) (n=25) | NR | NA

AF = atrial fibrillation; bpm = beats per minute; IQR = interquartile range; METS = metabolic equivalents; ml/kg/min=milliliters per kilogram per minute; NR = not reported; NS = not significant; RF = radiofrequency; SD = standard deviation; VO_2_ = volume of oxygen (measure of oxygen consumption); W = watts.

* Baseline scores were estimated from the graph provided.

##### Intermediate Outcomes

###### Freedom from Recurrence of Atrial Arrhythmias

Ten RCTs comparing RFA with medical therapy reported sufficient data on short-term freedom from recurrence of any atrial arrhythmia (including AF, atrial flutter, and atrial tachycardia) following the blanking period, which ranged from 1 to 3 months.36–39, 41, 43–47 The quality of all but one trial was considered fair, with one trial being considered good.45 Freedom from recurrence was variably defined across trials, with some trials defining it based on the presence of symptoms and others defining it based on duration and frequency of recurrent episodes. Of the 10 trials, 4 evaluated patients with paroxysmal AF,38, 44, 46, 47 4 evaluated patients with persistent AF,37, 39, 41, 43 and 2 included both paroxysmal and persistent AF patients.36, 45 There was substantial crossover from medical therapy to RFA, which exceeded 50 percent in six trials.38, 43–47 One trial provided comparative data up to 6 months only and thus was not included in the meta-analysis; 80.8 percent of patients who underwent RFA were free from arrhythmia recurrence compared to 0 percent who received medical therapy (Table 16). At 12 months, 73.1 percent of RFA patients were still free from recurrence. The pooled estimate across the remaining nine trials (N=1082) favored RFA (RR 2.62; 95% CI 1.90 to 3.96), however there was substantial heterogeneity across these trials (I^2^ = 84.2%; p=0.0001) (Figure 4). The pooled estimate from the four fair-quality trials of paroxysmal AF patients also favored RFA (RR 3.06; 95% CI 2.35 to 3.90) (531 patients).38, 44, 46, 47 There was not significant heterogeneity across these trials (I^2^ = 2.2%; p=0.381). Individual trials in patients with persistent AF or those with mixed populations also favored RFA.36, 39, 41, 43, 45 However, the pooled estimates for the persistent AF group and the mixed AF group were not statistically significant. Therefore, because results from individual trials were significant and because the pooled estimates were associated with substantial heterogeneity, the pooled estimates were considered to be misleading. Among the four studies that included only patients with persistent AF,37, 39, 41, 43 one was limited to patients with heart failure and an LVEF less than or equal to 35 percent39 and another was limited to patients with symptomatic heart failure and LVEF less than 50 percent.37 The other two studies excluded patients with LVEF less than 30 percent.41, 43 Further, the mean duration of AF prior to enrollment in the trials was quite different. One of the two studies that allowed both paroxysmal and persistent AF patients included only patients with diabetes mellitus.35 These differences in the patient characteristics might contribute to the substantial heterogeneity observed in the pooled estimates.

Three fair-quality RCTs comparing RFA with medical therapy reported on long-term (≥24 months) freedom from recurrence of any atrial arrhythmias among patients with paroxysmal AF.35, 42, 83 Mean followup was 24 months in two of the studies35, 42 and 48 months in the third.83 The pooled estimate across three trials of 619 patients favored RFA (RR 1.24; 95% CI 1.11 to 1.47) (Figure 5). There was not significant heterogeneity across these trials (I^2^ = 0%; p=0.388), potentially resulting from the very similar inclusion and exclusion criteria employed in these trials: all enrolled patients with at least two episodes of AF in the past 6 months and all excluded patients with appreciable left atrial enlargement, LVEF <35 or 40 percent or heart failure symptoms.35, 42, 83

The comparative observational studies provided limited information on freedom from recurrence of AF (Table 17). One fair-quality prospective cohort study of paroxysmal AF patients reported similar proportions of RFA and medical therapy patients with freedom from recurrence of AF at 12 months (65% vs. 68%, respectively).49 The other two studies reporting this outcome reported that 72 to 74 percent of RFA patients achieved freedom from recurrence but did not provide data for the medical therapy group.51, 52

Figure 4 Profile likelihood model meta-analysis of freedom from any arrhythmia recurrence within 12 months* of followup in RCTs comparing RFA with medical therapy†

RCT = randomized controlled trial; RFA = radiofrequency catheter ablation; RR = relative risk.

*For Stabile 2006, followup time included a 1-month blanking period, for a total of 13 months followup.

†The combined estimates for the persistent and mixed groups are not significant while each individual study provides significant results. Thus, the combined estimates are misleading and only combined estimates were reported for the paroxysmal group and all groups combined (overall).

‡All studies were in patients undergoing treatment as a second-line therapy (i.e., had failed prior medical therapy) with the exception of Wazni 2005 which was in patients treated as a first-line therapy.

Figure 4. This figure is a forest plot that displays freedom from recurrence of any arrhythmia following radiofrequency ablation (RFA) compared with medical therapy from nine randomized controlled trials (RCTs) with followup periods of 12 months or less. The pooled estimate across all trials favored RFA (relative risk [RR] 2.62; 95% confidence interval [CI] 1.90 to 3.96), however there was substantial heterogeneity across these trials. The pooled estimate from the four fair-quality trials of paroxysmal AF patients also favored RFA (RR 3.06; 95% CI 2.35 to 3.90) with no significant heterogeneity across trials. Individual trials in patients with persistent AF (3 trials) or those with mixed populations (2 trials) also favored RFA; however, the pooled estimates for these groups were not statistically significant and associated with substantial heterogeneity such that they were considered misleading and not included in the figure.

Figure 5 Profile likelihood model meta-analysis of freedom from any arrhythmia recurrence at followup times greater than 12 months in RCTs comparing RFA with medical therapy in patientswith paroxysmal AF

AF = atrial fibrillation; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation; RR = relative risk.

*Cosedis Nielsen 2012 and Morillo 2014 were in patients treated as a first-line therapy; Pappone 2011 was in patients undergoing treatment as a second-line therapy (i.e., had failed prior medical therapy).

Figure 5. This figure is a forest plot that displays freedom from recurrence of any arrhythmia following radiofrequency ablation (RFA) compared with medical therapy from three fair-quality randomized controlled trials (RCTs) with followup periods longer than 12 months (up to 48 months). All RCTs were in patients with paroxysmal atrial fibrillation and the pooled estimate favored RFA (relative risk 1.24; 95% confidence interval 1.11 to 1.47). There was not significant heterogeneity across these trials.

###### Reablation of Atrial Arrhythmias

Eight RCTs examined reablation of any arrhythmia within 12 months of followup,37–41, 43, 44, 46 three in patients with paroxysmal AF (n=184)38, 44, 46 and five in patients with persistent AF (n=246).37, 39–41, 43 All trials were fair-quality. The percentage of patients with paroxysmal AF who underwent reablation ranged from 0 to 43.3 percent. In the trials that only included persistent AF, the rate of reablation ranged from 8.1 to 53.8 percent with a pooled estimate of 25.5 percent (95% CI 13.6 to 42.6) (Figure 6).

One comparative observational study in paroxysmal AF patients reported reablation for AF recurrence within 12 months with a rate of 12.2 percent (n=82)52 (Table 17).

Four RCTs examined reablation of any arrhythmia at long-term followup, two through 24 months,35, 42 one through 48 months83 and one trial that primarily reported short-term outcomes but provided information on reablation beyond 12 months.46 All trials included only patients with paroxysmal AF (n=619). The quality of all trials was considered fair. The rate of reablation in that trial was 12.5 percent. The rate of reablation ranged from 13.6 to 49.2 percent during 24 months of followup.35, 42 The trial that examined outcomes over 48 months showed a reablation rate of 27.3 percent.83 The pooled estimate for the four trials was 24.2 percent (95% CI 12.6 to 41.5% (Figure 7).

One comparative observational study in a Medicare-relevant population of persistent AF patients examined reablation of any arrhythmia within a mean followup period of 60 months and reported a rate of 18.3 percent (n=153)48 (Table 17).

Figure 6 Reablation for any arrhythmia within 12 months following RFA in patients with paroxysmal and persistent AF

AF = atrial fibrillation; CHF = congestive heart failure; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation.

*Patients with heart failure (MacDonald 2011, Hunter 2014, and Jones 2013).

†The range of frequency for reablation was large and data were considered too sparse to provide a meaningful pooled estimate.

Figure 6. This figure is a bar graph that displays the percentage of patients who underwent re-abaltion for any type of arrhythmia following radiofrequency ablation (RFA) from eight fair-quality randomized controlled trials (RCTs) with followup periods of 12 months or less. The percentage of patients with paroxysmal atrial fibrillation (AF) who underwent reablation ranged from 0 to 43.3 percent across three trials. In the five trials that only included persistent AF, the rate of reablation ranged from 8.1 to 53.8 percent with a pooled estimate of 25.5 percent (95% confidence interval [CI] 13.6 to 42.6). Three of these latter trials were also in patients with concomitant heart failure and percentages ranged from 20.0 to 53.8 percent, with a pooled estimate of 34.0 percent (95% CI 19.3 to 52.6).

Figure 7 Reablation for any arrhythmia at long-term followup (>12 months) after RFA from RCTs of patients with paroxysmal AF

AF = atrial fibrillation; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation.

Figure 7. This figure is a bar graph that displays the percentage (as reported or calculated) of patients who underwent re-abaltion for any type of arrhythmia following radiofrequency ablation (RFA) from four fair-quality randomized controlled trials (RCTs) with followup periods of longer than 12 months (up to 48 months). All RCTs were in patients with paroxysmal atrial fibrillation. The rate of reablation ranged from 12.5 to 49.2 percent, with a pooled percent of 24.2 (95% confidence interval 12.6 to 41.5).

###### Maintenance of Sinus Rhythm

Four RCTs examined maintenance of sinus rhythm; two included patients with paroxysmal AF38, 44 and two included patients with persistent AF.39, 40 The latter two studies were also limited to patients with heart failure. Except for one trial that had a followup period of 6 months,40 these studies had a followup period of 12 months. The quality of all four trials was considered fair. None of the long-term studies reported on maintenance of sinus rhythm.

Of the two RCTs that examined maintenance of sinus rhythm in patients with paroxysmal AF,38, 44 one showed no difference between medical therapy and RFA (87% vs. 88% during 12 months of followup)38 and the other showed a significant improvement in maintenance of sinus rhythm with RFA (92.9% vs. 35.4% during 12 months of followup).44 Both trials that examined maintenance of sinus rhythm in patients with persistent AF and heart failure showed a significant difference in this outcome with RFA (88% vs. 7.7% during 12 months of followup in one study39 and 50% vs. 0% during 6 months in another40) (Table 16).

Four comparative observational studies reported on maintenance of sinus rhythm; two included patients with paroxysmal AF,52, 54 one included patients with persistent AF48 and one included patients with paroxysmal or persistent AF.51 Followup was 12 months in two studies,52, 54 15 months in one study,51 and 60 months in one study.48 The quality of the four studies was considered fair48, 49, 52, 53 and of the other two was poor.51, 54

The rate of maintenance of sinus rhythm during 12 months of followup in patients with paroxysmal AF included in one comparative observational study was 71.1 percent in the RFA arm and 47.1 percent in the medical therapy.54 In another study of patients with paroxysmal AF the rate of maintenance of sinus rhythm was 72 percent in the RFA arm vs. 20.2 percent in the medical therapy arm.52 In a study of Medicare-relevant (age ≥75 years) patients with persistent AF, the rate of maintenance of sinus rhythm was 58 percent in the RFA arm vs. 43 percent in the medical therapy arm during a mean followup period of 60 months.48 In a study that followed patients with paroxysmal or persistent AF for a mean of 15 months, the rate of maintenance of sinus rhythm was 82 percent in the RFA arm and 40 percent in the medical therapy arm (Table 17).51

###### Rehospitalization for Cardiovascular Causes

Four trials provided information on rehospitalization for cardiovascular causes (Table 16). One trial in patients with paroxysmal AF provided information on rehospitalizations up to 12 months44 and then at 48 months in a separate publication.83 RFA was used as a second-line treatment in this trial. Two additional trials in those with paroxysmal AF reported on rehospitalization at 12 months46 and 24 months respectively.35 Both of these studies used RFA as a first-line treatment. One trial in patients with persistent AF reported on rehospitalization up to 12 months.41 All trials were considered to be of fair quality. Overall, studies did not provide detail regarding reasons for hospitalization and the extent to which hospitalization for reablation procedures or crossover from medical therapy to ablation were included. This may at least partially explain discrepancies in rehospitalization frequency across studies and time frames.

Overall, hospitalization was more frequent in patients who received medical therapy. In those with paroxysmal AF, rehospitalization was more common in the medical treatment groups by 12 months across two trials.44, 46 This was also evident in the trial population followed to 48 months.83 In this trial, the 12 months results do not include the hospitalization for crossover to ablation;44 at 48 months, however, results do include repeat procedures and crossover to ablation.83 The other trial in patients with paroxysmal AF reported no hospitalizations in those with AF and only two in the medical treatment group.

In patients with persistent AF, rehospitalization was more common among those receiving medical therapy in one study.41 Recurrent arrhythmia was cited as the reason.

Of the six comparative observational studies, one fair-quality administrative database study in the general population reported a lower annualized rate of hospitalization for heart failure (1.5%) following RFA versus the medical treatment arm (2.2%) (Table 17). The Cox regression unadjusted hazard ratio for heart failure hospitalization in the ablation versus medical treatment cohorts was 0.69 (95% CI 0.42 to 1.15, p=0.158). In multivariable models, there was no association between age ≥65 years and rates of hospitalization for heart failure at 27 months.

###### Atrial Fibrillation Burden

One RCT reported on AF burden in patients with paroxysmal AF defined as percentage of time in AF on each Holter recording (obtained at each clinic visit) and as percentage of time in AF on all the Holter recordings obtained during the 24-month followup (cumulative burden).35 The per-visit burden was significantly lower in the RFA arm (9%) versus the medical therapy arm (18%) (p=0.007) and the cumulative burden was 13 percent versus 19 percent, respectively (p=0.10). In second study of paroxysmal AF patients, the median reduction in AF over 24 hours for each Holter recordings was significantly higher in the RFA arm than the medical therapy arm (10 vs. 3.2 minutes, p=0.0001) (Table 16).38

###### Reduction in Use of Antiarrhythmic Medications

Only one study reported on reduction in use of antiarrhythmic medications. This fair-quality study was a retrospective propensity matched analysis of the MarketScan Research Database between 2005 and 2009 of catheter ablation (n=801) versus medical therapy (n=801).50 A significant reduction in the use of antiarrhythmic medications in the ablation arm compared with the medical therapy arm at 12 months (49% vs. 80%, p<0.001), 24 months (40% vs. 72%, p<0.001) and 36 months of followup (39% vs. 63%, p<0.001) was seen (Table 17).

###### Change in Cardiac Chamber Size and Function

Left Atrial Size: A total of four RCTs assessed the effect of RFA on left atrial size.38–40, 44 Two examined left atrial dimension on echocardiography in patients with paroxysmal AF (n=310),38, 44 one assessed left atrial area on echocardiography in patients with persistent AF (n=52)39 and one assessed left atrial end-diastolic area using cardiac MRI in patients with persistent AF(n=41) (Table 18).40 There was no significant difference in the left atrial size between RFA and medical therapy arm in the two studies that examined patients with paroxysmal AF.38, 44 There was a significant reduction in the left atrial size at 6 and 12 months in the RFA arm compared with the medical therapy arm in the study by Jones and colleagues and a trend toward a reduction in left atrial size at 6 months with RFA compared with medical therapy in the study by MacDonald and colleagues.39, 40

Only one comparative observational study examined the association between RFA and left atrial size and showed no significant difference between RFA and medical therapy (Table 17).49

Left Ventricular Size: Three RCTs examined the effect of RFA on left ventricular size;37, 38, 40 two using echocardiography, one in patients with paroxysmal AF38 and other in patients with persistent AF,37 and the third using cardiac MRI in patients with persistent AF.40 Except for one study, they showed no significant difference in left ventricular size between RFA and medical therapy at 6 months in one study40 and 12 months in the other (Table 18).38 The study by Hunter et al showed a significant reduction in left ventricular size with ablation at 6 months.37

Left Ventricular Ejection Fraction: Four RCTs37–40 examined the effect of RFA on the left ventricular ejection fraction, using echocardiography in one study in patients with paroxysmal AF38 and another study in patients with persistent AF,37 and radionuclide ventriculography in the other two that included patients with persistent AF (Table 18).39, 40 In the study by Jais et al.,38 there was no significant difference in change of left ventricular ejection fraction between RFA and medical therapy at 12 months. In the study by MacDonald and colleagues, there was a significant difference in the magnitude of improvement in the left ventricular ejection fraction with RFA vs. medical therapy at 6 months.40 In the study by Jones and colleagues, there was a trend toward greater improvement in left ventricular ejection fraction at 12 months (p=0.06).39 In the study by Hunter et al, there was a significant improvement (mean increase of 8.1%) in the LVEF within 6 months of followup in the ablation group.37

###### Change in Biomarkers

Three RCTs compared RFA with medical therapy with regard to their effect on brain natriuretic peptide (BNP) in patients with persistent AF (Table 18).37, 39, 40 In one study, there was no significant difference between the two arms at 6 months.40 In another study, the reduction in BNP was significantly greater in the RFA arm than in the medical therapy arm at 6 months and 12 months.39 In the study by Hunter et al., at 6 months, BNP was 126 pg/ml in the ablation group and 327 pg/ml in the medical therapy group (p=0.014).37

Table 16 Intermediate efficacy outcomes for RCTs comparing RFA with medical therapy^*^

Outcome | AF Type (1^st^/2^nd^ line therapy) | Study | Followup | RFA % (n/N) | Medical Therapy % (n/N) | p-value
Freedom From Recurrence (Any Arrhythmia) | Persistent (1^st^/2^nd^ line) | Hunter 2014^37^ (heart failure) | 6 months | 80.8% (21/26)^†^ | 0% (24/24)^†^ | NR
Freedom From Recurrence (Any Arrhythmia) | Persistent (1^st^/2^nd^ line) | Hunter 2014^37^ (heart failure) | 12 months | 73.1% (19/26)^†^ | NR | NR
Maintenance of Sinus Rhythm | Paroxysmal (2^nd^ line) | Jais 2008^38^ | 12 months | 88% (46/52)^‡^ | 87% (48/55)^‡^ | NR
Maintenance of Sinus Rhythm | Paroxysmal (2^nd^ line) | Pappone 2006^44^ | 12 months | 92.9% (92/99) | 35.4% (35/99) | NR
Maintenance of Sinus Rhythm | Persistent (1^st^/2^nd^ line) | Jones 2013^39^ (Heart failure) | 12 months | 88.0% (22/25) | 7.7% (2/26) | NR
Maintenance of Sinus Rhythm | Persistent (2^nd^ line) | MacDonald 2011^40^ (Heart failure) | 6 months | 50.0% (10/20) | 0% (0/18) | NR
Rehospitalization For Cardiovascular Causes | Paroxysmal (1^st^ line) | Wazni 2005^46^ | 12 months | 9.4% (3/32) | 54.3% (19/35) | NR
Rehospitalization For Cardiovascular Causes | Paroxysmal (1^st^ line) | Cosedis Nielsen 2012^35^ | 24 months | 0% (0/146) | 1.4% (2/148)^§^ | NR
Rehospitalization For Cardiovascular Causes | Paroxysmal (2^nd^ line) | Pappone 2006^44^ | 12 months | 9.1% (9/99) (24 admissions)^**^ | NR (NR/99) (167 admissions)^††^ | NR
Rehospitalization For Cardiovascular Causes | Paroxysmal (2^nd^ line) | Pappone 2011^83^ | 48 months | NR (61 admissions)^**^ | NR (325 admissions)^††^ | NR
Rehospitalization For Cardiovascular Causes | Persistent (2^nd^ line) | Mont 2014^41^ | 12 months | 2.0% (2/98)^‡‡^ | 6.3% (3/48)^‡‡^ | NR
AF Burden % of time in AF on each Holter recording (per-visit burden) | Paroxysmal (1^st^ line) | Cosedis Nielsen 2012^35^ | 24 months | [underlined: n=146] 9%^§§^ | [underlined: n=148] 18%^§§^ | 0.007
AF Burden % of time in AF on all the Holter recordings obtained during followup (cumulative burden) | Paroxysmal (1^st^ line) | Cosedis Nielsen 2012^35^ | 24 months | [underlined: n=146] 13%^§§^ | [underlined: n=148] 19%^§§^ | 0.10
AF Burden Median (IQR) reduction in AF over 24 hours for each Holder recording (minutes) | Paroxysmal (2^nd^ line) | Jais 2008^38^ | Baseline 12 months | [underlined: n=53] 14 (0–578) 10.0 (0–588) | [underlined: n=59] 14 (0–215) 3.2 (0–155) | 0.69 0.0001

AF = atrial fibrillation; IQR = interquartile range; NR = not reported; RFA = radiofrequency ablation.

* A meta-analysis was performed for the outcomes freedom from recurrence (any arrhythmia) (see Figures 4 and 5) and reablation (see Figures 6 and 7)

† According to the methods, freedom recurrence was defined as freedom from documented AF/atrial tachycardia lasting ≥30 secondary after the 3-month blanking period. As reported in the results, it appears that 4 patients with early AF recurrences (<3 months) were included in this estimate (for the purposes of this report, this is considered an adverse event). None of these patients received further treatment for the recurrence, however, so we are making the assumption that they remained in AF through the 6 and 12 months followup. Therefore, these patients are counted under both efficacy and adverse events in this report.

‡ Only percent provided. Back calculated using ITT to get “n’s”.

§ Hospitalization for congestive heart failure.

** Including repeat procedures. Pappone 2006 and Pappone 2011 represent the same population with different followup.

†† At 12 months, results do not include the hospitalization for crossover to ablation; at 48 months, however, results do include repeat procedures and crossover to ablation. Pappone 2006 and Pappone 2011 represent the same population with different followup.

‡‡ Due to arrhythmia recurrences.

§§ 90^th^ percentile of arrhythmia burden

Table 17 Intermediate effectiveness outcomes for comparative observational studies comparing RFA with medical therapy

Outcome | AF Type^*^ | Study | Followup | RFA % (n/N) | Medical Therapy % (n/N) | p-value
Freedom from recurrence (any arrhythmia) | Mixed | Rossillo 2008^51^ | Mean 15 months | 74% (63/85) | NR | NA
Freedom from recurrence (AF only)^†^ | Paroxysmal | Lan 2009^‡,49^ | 12 months | 65% (78/120) | 68.3% (82/120) | NR
Freedom from recurrence (AF only)^†^ | Paroxysmal | Sang 2013^52^ | 12 months | 72% (53/82) | NR | NA
Reablation for any arrhythmia | Persistent | Blandino 2013^§,48^ | Mean 60 months | 18.3% (28/153) | NR | NA
Reablation for AF | Paroxysmal | Sang 2013^52^ | 12 months | 12.2% (10/82) | NR | NA
Maintenance of sinus rhythm^†^ | Paroxysmal | Yu 2012^54^ | 12 months | 71.1% (69/97) | 47.1% (48/102) | NR
Maintenance of sinus rhythm^†^ | Paroxysmal | Sang 2013^52^ | 12 months | 72% (59/82) | 20.2% (17/84) | <0.001
Maintenance of sinus rhythm^†^ | Persistent | Blandino 2013^§,48^ | Mean 60 months | 58% (88/153) | 43% (111/259) | 0.003
Maintenance of sinus rhythm^†^ | Mixed | Rossillo 2008^51^ | Mean 15 months | 82% (70/85) | 40% (34/85) | NR
Reduction in antiarrhythmic medication^**^ | Mixed | Reynolds 2012^50^ | | [underlined: N=801] | [underlined: N=801]
Reduction in antiarrhythmic medication^**^ | Mixed | Reynolds 2012^50^ | Baseline | 79% | 79% | NS
Reduction in antiarrhythmic medication^**^ | Mixed | Reynolds 2012^50^ | 6 months | 70% | 90% | <0.001
Reduction in antiarrhythmic medication^**^ | Mixed | Reynolds 2012^50^ | 12 months | 49% | 80% | <0.001
Reduction in antiarrhythmic medication^**^ | Mixed | Reynolds 2012^50^ | 18 months | 42% | 75% | <0.001
Reduction in antiarrhythmic medication^**^ | Mixed | Reynolds 2012^50^ | 24 months | 40% | 72% | <0.001
Reduction in antiarrhythmic medication^**^ | Mixed | Reynolds 2012^50^ | 30 months | 37% | 69% | <0.001
Reduction in antiarrhythmic medication^**^ | Mixed | Reynolds 2012^50^ | 36 months | 39% | 63% | <0.001
Left atrial size (mm), mean [anteroposterior diameter at end- systole, transthoracic echocardiography] | Paroxysmal | Lan 2009^‡,49^ | | [underlined: n=120] | [underlined: n=120]
Left atrial size (mm), mean [anteroposterior diameter at end- systole, transthoracic echocardiography] | Paroxysmal | Lan 2009^‡,49^ | Baseline | 34.66 | 34.69 | NR
Left atrial size (mm), mean [anteroposterior diameter at end- systole, transthoracic echocardiography] | Paroxysmal | Lan 2009^‡,49^ | 3 months | 33.82 | 34.66 | NR
Left atrial size (mm), mean [anteroposterior diameter at end- systole, transthoracic echocardiography] | Paroxysmal | Lan 2009^‡,49^ | 6 months | 33.91 | 34.90 | NR
Left atrial size (mm), mean [anteroposterior diameter at end- systole, transthoracic echocardiography] | Paroxysmal | Lan 2009^‡,49^ | 9 months | 34.15 | 35.26 | NR
Left atrial size (mm), mean [anteroposterior diameter at end- systole, transthoracic echocardiography] | Paroxysmal | Lan 2009^‡,49^ | 12 months | 34.49 | 35.80 | NR

AF = atrial fibrillation; mm = millimeter; NA = not applicable; NR = not reported; RFA = radiofrequency ablation.

* All treatments were a second-line therapy for AF.

† Yu et al. 2012 and Rosillo et al. 2008 seem to be using maintenance of sinus rhythm and freedom from AF recurrence interchangeably. Only maintenance of sinus rhythm was reported for these studies.

‡ Data from the circumferential pulmonary vein ablation (CPVA; 32/60) and the segmental pulmonary vein isolation (SPVI; 46/60) groups were combined to form one radiofrequency ablation group; similarly data were combined from the amiodarone only (AMIO; 35/60) and the amiodarone + losartan (AMIO+LO) groups to form one medical therapy group. Standard deviations were provided for all 4 groups.

§ Represents the Medicare population (age ≥75 years). All other studies represent the general adult population.

** These values are estimated from Figure 2 in the report. Authors also report patterns of rate control medication usage and Warfarin usage over the study period which were nearly identical between the cohorts over the entire timeframe (75% to 70% and 70% to 50%, respectively) with the exception of day 8 to 6 months, during which they were used more often in the ablation patients (p=0.019, and p<0.001, respectively).

Table 18 Cardiac chamber size/function and biomarkers reported by RCTs comparing RFA with medical therapy

Outcome (mode of measurement) | AF Type (1^st^/2^nd^ line therapy) and Study | Followup | RFA | Medical Therapy | p- value
Left atrial size, mean ± SD Left atrial dimension (parasternal long axis, mm) (Echo) | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 39.5 ± 5.6 (n=53) | 40.0 ± 5.7 (n=59) | NR
Left atrial size, mean ± SD Left atrial dimension (parasternal long axis, mm) (Echo) | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 38.7 ± 7.0 (n=53) | 38.9 ± 6.2 (n=59) | 0.92
Left atrial size, mean ± SD Left atrial dimension (parasternal long axis, mm) (Echo) | Paroxysmal (2^nd^ line), Pappone 2006^44^ | Baseline | 40 ± 6 (n=99) | 38 ± 6 (n=99) | 0.25
Left atrial size, mean ± SD Left atrial dimension (parasternal long axis, mm) (Echo) | Paroxysmal (2^nd^ line), Pappone 2006^44^ | 12 months | 36 ± 6 (n=99) | NR (n=99) | NA
Left atrial size, mean (95% CI) Left atrial area (cm^2^) (Echo) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | Baseline | NR | NR | NR
Left atrial size, mean (95% CI) Left atrial area (cm^2^) (Echo) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | Mean difference between groups at: 6 months | −4.96 (−7.23 to −2.68)^*^ | — | 0.001
Left atrial size, mean (95% CI) Left atrial area (cm^2^) (Echo) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | Mean difference between groups at: 12 months | −6.22 (−9.17 to −3.27)^*^ | — | 0.001
Left atrial size, mean ± SD Left atrial end-diastolic area (mm^2^) (CMR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | Baseline | 3291.1 ± 766.1 (n=19) | 3214.5 ± 594.1 (n=18) | NR
Left atrial size, mean ± SD Left atrial end-diastolic area (mm^2^) (CMR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | 6 month change | −237.0 ± 490.4 (n=19) | +35.5 ± 364.0 (n=18) | 0.06
Left ventricular size, mean ± SD End-diastolic dimension (mm) (Echo) | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 51.9 ± 4.2 (n=53) | 50.5 ± 7.7 (n=59) | NR
Left ventricular size, mean ± SD End-diastolic dimension (mm) (Echo) | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 50.0 ± 5.2 (n=53) | 51.0 ± 4.5 (n=59) | 0.35
Left ventricular size, mean ± SD End-diastolic volume (ml) (CMR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | Baseline | 244.1 ± 94.0 (n=19) | 215.0 ± 74.7 (n=18) | NR
Left ventricular size, mean ± SD End-diastolic volume (ml) (CMR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | 6 month change | −12.6 ± 51.7 (n=19) | −9.4 ± 35.7 (n=18) | 0.80
Left ventricular size, mean ± SD End-systolic volume (ml) (CMR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | Baseline | 163.8 ± 83.2 (n=19) | 126.3 ± 58.4 (n=18) | NR
Left ventricular size, mean ± SD End-systolic volume (ml) (CMR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | 6 month change | −20 ± 50.2 (n=19) | −10.6 ± 32.2 (n=18) | 0.50
Left ventricular size, mean (95% CI) End-systolic volume (ml) (Echo) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | Baseline | NR | NR | NA
Left ventricular size, mean (95% CI) End-systolic volume (ml) (Echo) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | 6 month change | −14.2% (−26.2% to −2.2%) (n=25) | +4.7% (−7.9% to 17.2%) (n=23) | 0.030
LVEF (%), mean ± SD (Echo) | Paroxysmal (2^nd^ line), Jais 2008^38^ | Baseline | 63.1% ± 11.0% (n=53) | 65.6% ± 7.2% (n=59) | NR
LVEF (%), mean ± SD (Echo) | Paroxysmal (2^nd^ line), Jais 2008^38^ | 12 months | 65.4% ± 8.9% (n=53) | 65.4% ± 5.9% (n=59) | 0.99
LVEF (%), mean ± SD (Echo) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | Baseline | 31.8% ± 7.7% (n=26) | 33.7% ± 12.1% (n=24) | NR
LVEF (%), mean ± SD (Echo) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | 6 month change^†^ | +8.1% (95% CI 3.0 to 13.1) (n=25) | −3.6% (95% CI −7.7 to 0.5) (n=23) | <0.001
LVEF (%), mean ± SD (RNVG) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | Baseline | 21.5% ± 8.3% (n=26) | 24.9% ± 7.2% (n=26) | .13
LVEF (%), mean ± SD (RNVG) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | 12 month change | +10.9% ± 11.5% (n=26) | +5.4% ± 8.5% (n=26) | 0.06
LVEF (%), mean ± SD (RNVG) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | Baseline | 15.1% ± 6.5% (n=20) | 19.6% ± 5.9% (n=17) | NR
LVEF (%), mean ± SD (RNVG) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | 6 month change | +8.2% ± 12.0% (n=20) | +1.4% ± 5.9% (n=17) | 0.03
LVEF (%), mean ± SD (CMR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | Baseline | 36.1% ± 11.9% (n=19) | 42.9% ± 9.6% (n=18) | NR
LVEF (%), mean ± SD (CMR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | 6 month change | +4.5% ± 11.1% (n=19) | +2.8% ± 6.7% (n=18) | 0.60
Brain natriuretic peptide (pg/ml) mean ± SD (95% CI), median (IQR) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | Baseline | 412 ± 324 (n=26) | 283 ± 285 (n=26) | .13
Brain natriuretic peptide (pg/ml) mean ± SD (95% CI), median (IQR) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | 6 months change | NR (n=26) | NR (n=26) | 0.04^‡^
Brain natriuretic peptide (pg/ml) mean ± SD (95% CI), median (IQR) | Persistent (1^st^/2^nd^ line), Jones 2013^39^ (heart failure) | 12 month change | −124 (−284 to 0) (n=26) | −18 (−86 to +31) (n=26) | 0.04
Brain natriuretic peptide (pg/ml) mean ± SD (95% CI), median (IQR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | Baseline | 2550 ± 2150 (n=20) | 1846 ± 1687 (n=18) | NR
Brain natriuretic peptide (pg/ml) mean ± SD (95% CI), median (IQR) | Persistent (2^nd^ line), MacDonald 2011^40^ (heart failure) | 6 month change | −196 ± 1469 (n=20) | +85 ± 648 (n=28) | 0.45
Brain natriuretic peptide (pg/ml) mean ± SD (95% CI), median (IQR) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | Baseline | 400^§^ | 650^§^ | NA
Brain natriuretic peptide (pg/ml) mean ± SD (95% CI), median (IQR) | Persistent (1^st^/2^nd^ line), Hunter 2014^37^ (heart failure) | 6 months^†^ | 126 (95% CI 63 to 189) (n=25) | 327 (95% CI 172 to 481) (n=23) | 0.01

AF = atrial fibrillation; CI = confidence interval; cm = centimeter; CMR = cardiovascular magnetic resonance; Echo = transthoracic echocardiography; IQR = interquartile range; LVEF = left ventricular ejection fraction; pg/ml = picograms per milliliter; mm = millimeter; NA = not applicable; NR = not reported; RCT = randomized controlled trial; RFA = radiofrequency ablation; RNVG = radionuclide ventriculography; SD = standard deviation.

* Mean difference (95% CI) in the ablation compared with medical therapy group at 6 and 12 months.

† The improvement in the ablation group was sustained at 1 year; no comparison data available for the medical therapy group.

‡ There was a significant reduction in brain natriuretic peptide at 6 months in the ablation group compared with the medical therapy group.

§ Baseline scores were estimated from the graph provided.

### Cryoablation Versus Medical Therapy

#### Description of Included Studies

One multi-center RCT (26 centers within North America) compared cryoballoon ablation (n=163) with medical therapy (n=82) over 12 months of followup, which included a 3 month blanking period.86 Patients had highly symptomatic paroxysmal (78%) or persistent (22%) AF. The trial was funded by Medtronic Inc. Conflicts of interests were reported and were in the form of research funding, consultant fees, and honoraria.

The study population was predominantly male (77.1%) and had a mean age of 57 years (Table 19). All patients had previously failed medical therapy. Almost all patients (93.5%) had either no or Class I heart failure. Patients in the cryoballoon ablation arm were allowed to be treated with AADs during the blanking period, after which the drug was discontinued. Within the drug therapy arm, patients received flecainide, propafenone, or sotalol; AF drugs such as amiodarone and dofetilide were not permitted since they did not have FDA approval for treatment of paroxysmal AF. Patients were only allowed to crossover to cryoballoon ablation after meeting protocol-defined effectiveness failure endpoints. Over the course of the study 65 of the 82 drug-treated patients (79%) crossed over to ablative therapy. The median time to crossover was 186 days (range 29 to 364 days).

The cryoballoon ablation therapy had as a goal electrical PVI of the four major pulmonary veins as confirmed by entrance and/or exit block, with additional focal cryoballoon ablation deliveries allowed at investigator discretion (e.g., for focal triggers, cavotricuspid isthmus-dependent atrial flutter). One repeat cryoballoon ablation procedure was allowed during the blanking period and 31 (19%) patients had a second ablation during this time. No reablation occurred after the blanking period. A substudy of this trial examining the significance of early recurrence of AF in those randomized to cryoballoon ablation is also included; however it contributed limited evidence since it did not provided comparative data.73

There were no observational studies of cryoballoon or focal cryoablation versus medical therapy.

Table 19 Patient characteristics and overview of study characteristics for the STOP AF Pivotal RCT comparing cryoballoon ablation with medical therapy in patients with paroxysmal/early persistent AF

Author (Year) Therapy Sample Size | | Packer 2013^72^ Cryoballoon ablation (n=163) | Packer 2013^72^ Medical (n=82)
Patient Demographics | Male, % (n) | 76.7 (125) | 78.0 (64)
Patient Demographics | Age (years); mean ± SD | 57 ± 9 | 56 ± 9
Patient Demographics | AF duration (years) | NR | NR
Patient Demographics | AF episodes (past 2 months); mean ± SD | 24 ± 42 | 21 ± 32
Patient Demographics | Left atrial size (mm); mean ± SD | 40 ± 5 | 41 ± 6
Patient Demographics | LVEF (%), mean ± SD | 60 ± 6 | 61 ± 6
Patient Demographics | 1st/2nd line therapy | 2^nd^ line | 2^nd^ line
Patient Demographics | Special population | None | None
Comorbidities, % (n) | Hypertension | 41.1 (67) | 45.1 (37)
Comorbidities, % (n) | Coronary artery disease | 8.0 (13) | 9.8 (8)
Comorbidities, % (n) | NYHA class II | 6.7 (11) | 6.1 (5)
Comorbidities, % (n) | History of atrial flutter | 46.0 (75) | 43.9 (36)
Comorbidities, % (n) | Prior cardioversion | 22.7 (37) | 20.7 (17)
Comorbidities, % (n) | Diabetes | 6.7 (11) | 8.5 (7)
Comorbidities, % (n) | CHADS2 score, mean ± SD | 0.6 ± 0.7 | 0.6 ± 0.7
Study Characteristics | Followup period | 12 months | 12 months
Study Characteristics | Completed followup, % (n) | 100 (163) | 96.3 (7)
Study Characteristics | Blanking period | 3 months | 3 months
Study Characteristics | Crossover, % (n) | None | 79.3 (65)
Study Characteristics | Use of AADs in ablation group | Flecainide, propafenone, or sotalol during the blanking period only; after blanking period, previously ineffective drugs permitted

AAD = antiarrhythmic drug; AF = atrial fibrillation; CHADS2 = Congestive heart failure, Hypertension, Age, Diabetes, Stroke System; IQR = interquartile range; LVEF = left ventricular ejection fraction; NR = not reported; NYHA = New York Heart Association; RCT = randomized controlled trial; SD = standard deviation; STOP AF = Sustained Treatment of Paroxysmal Atrial Fibrillation.

#### Detailed Synthesis

##### Primary Outcomes

###### All-Cause and Cardiovascular Mortality >30 days

Within the included RCT,86 there was one unrelated death from a myocardial infarction in the cryoballoon ablation strategy at 10 months (Table 20). Patients were only followed for 12 months after treatment initiation and so longer-term all-cause or cardiovascular mortality evidence was not available.

###### Stroke >30 Days

Within the included RCT,86 there were three strokes in patients who either received cryoballoon ablation initially or who crossed over to ablation following medical therapy (Table 20). An additional four patients had nonprocedural-related cerebral vascular events over the 12 months of followup; all recovered without residual neurological deficits. Patients were only followed for 12 months after treatment initiation and so longer-term evidence regarding stroke events was not available. It is not clear that anticoagulation prior to ablation was adequate but appeared to be adequate during the procedure. Anticoagulation was required for the first 3 months after ablation and was discontinued at the investigators discretion.

###### Transient Ischemic Attacks >30 Days

There were no patients who experienced a TIA after 30 days (Table 20); no data provided on longer-term TIA outcomes.

###### Myocardial Infarction >30 Days

Within the included RCT,86 there was one myocardial infarction within the cryoballoon ablation patients with one being fatal (10 months following treatment) (Table 20). There was no evidence on longer-term myocardial infarction outcomes given the 12-month followup limitation.

###### Congestive Heart Failure

Within the included RCT,86 one patient was hospitalized for AF-related CHF (Table 20). There was no evidence in longer-term CHF outcomes given the 12-month followup limitation.

###### Health-Related Quality of Life

Within the included RCT,86 patients’ overall SF-36 was assessed at baseline and then during followup. The study notes that improvements in SF-36 quality-of-life scores were seen in the cryoballoon ablation group; however, the scores were not reported. Similar data regarding the quality-of-life findings in the medical therapy patients were not reported.

##### Intermediate Outcomes

###### Freedom from Protocol Defined Treatment Failure

The primary efficacy outcome for this trial was freedom from chronic treatment failure defined as any detectable AF after the blanking period, use of a nonstudy antiarrhythmic drug, or any nonprotocol intervention for AF (i.e., RF ablation). After 12 months of followup a significantly greater number of patients in the cryoballoon ablation group were free from protocol defined treatment failure (69.9%) compared with the medical therapy group (69.9% vs. 7.3%; p<0.001) (Table 20).86 At the end of the 12 months, 26 percent of the cryoballoon ablation patients were taking AADs. During a follow up of 12 months (after the blanking period), 41 patients experienced AF recurrence resulting in 74.8 percent of patients experiencing freedom from AF in the ablation group; no data were reported for the medical therapy group.73

###### Atrial Flutter

Within the included RCT,86 six patients (3.7%) reported atrial flutter during 12-month followup. In comparison, 12 (14.6%) of the drug-treatment patients reported atrial flutter during this same time period (p=NR) (Table 20).

###### Reduction in Arrhythmia-Related Symptoms

Symptomatic AF occurrence fell from 100 percent at baseline to 19 percent at 12 months in the cryoballoon ablation group. Similarly, compared with baseline, arrhythmia-related symptoms were reduced in cryoballoon ablation patients by 12 months with any AF symptoms reduced from 100 percent to 20 percent, dizziness from 48 percent to 9 percent, palpitations from 86 percent to 25 percent, and fatigue from 76 percent to 13 percent (Table 20).86 The authors note that these symptomatic improvements were confirmed by improvements in the SF-36 quality-of-life subscores (no data provided). Similar data regarding the symptom improvement in the drug treated patients were not reported.

Table 20 Efficacy outcomes from the STOP AF pivotal RCT comparing cryoballoon ablation with medical therapy in patients with paroxysmal/early persistent AF72

Type of Outcome | Outcome | Followup | Cryoballoon ablation^*^ % (n/N) | Medical Therapy^*^ % (n/N) | p- value
Primary Outcomes | Mortality (all-cause) >30 days | 12 months | 0.6% (1/163)^†^ | 0% (0/79) | NR
Primary Outcomes | Mortality (cardiovascular) >30 days | 12 months | 0.6% (1/163)^†^ | 0% (0/79) | NR
Primary Outcomes | Stroke (any type) >30 days | 12 months | 1.8% (3/163)^‡^ | 0% (0/79) | NR
Primary Outcomes | Myocardial infarction >30 days | 12 months | 0.6% (1/163)^†^ | 0% (0/79) | NR
Primary Outcomes | Transient ischemic attack >30 days | 12 months | 0% (0/163) | 0% (0/79) | NR
Primary Outcomes | Congestive heart failure (requiring hospitalization, timing NR) | 12 months | 0.6% (1/163) | 0% (0/79) | NR
Intermediate Outcomes | Freedom from protocol defined treatment failure^§^ | 12 months | 69.9% (114/163) | 7.3% (6/82) | <0.001
Intermediate Outcomes | Reduction in arrhythmia-related AF symptoms^††^ | Baseline | 100% (163/163) | NR | NA
Intermediate Outcomes | Reduction in arrhythmia-related AF symptoms^††^ | 12 months | 20% (33/163) | NR | NA
Intermediate Outcomes | Reduction in arrhythmia-related dizziness symptoms^††^ | Baseline | 48% (78/163) | NR | NA
Intermediate Outcomes | Reduction in arrhythmia-related dizziness symptoms^††^ | 12 months | 9% (15/163) | NR | NA
Intermediate Outcomes | Reduction in arrhythmia-related palpitation symptoms^††^ | Baseline | 86% (140/163) | NR | NA
Intermediate Outcomes | Reduction in arrhythmia-related palpitation symptoms^††^ | 12 months | 25% (41/163) | NR | NA
Intermediate Outcomes | Reduction in arrhythmia-related fatigue symptoms^††^ | Baseline | 76% (124/163) | NR | NA
Intermediate Outcomes | Reduction in arrhythmia-related fatigue symptoms^††^ | 12 months | 13% (21/163) | NR | NA
Intermediate Outcomes | Atrial Flutter | 12 months | 3.7% (6/163) | 14.6% (12/82) | NR

AF = atrial fibrillation; MI = myocardial infarction; NA = not applicable; NR = not reported; RCT = randomized controlled trial; STOP AF = Sustained Treatment of Paroxysmal Atrial Fibrillation; TIA = transient ischemic attack.

* No patient was lost to followup in the cryoballoon group; 3 patients were lost to followup in the medical group and, over the course of the study, 79% (65/82) crossed over to ablative intervention.

† Fatal MI deemed unrelated to procedure (same patient).

‡ Nonprocedural-related as determined by authors. Include: 1 small hemorrhagic stroke on day 183, 1 lacunar infarct of indeterminate age on CT examination on day 51, and 1 subarachnoid hemorrhage on day 260 in a patient on aspirin.

§ Defined by the absence of: 1) any detectable AF after the blanking period; 2) use of a nonstudy, antiarrhythmic drug; or 3) any nonprotocol intervention for AF (i.e., RF ablation).

** As treated analysis only. This outcome is comparing the patients who underwent ablation as intended (randomized ablation group) to those patients who underwent ablation after crossing over from medical therapy (65 patients from the medical group crossed over to ablation during the study period).

†† Authors only report %’s at baseline and 12 months. However, these results are from the intention-to-treat analysis so back-calculations were done to get the number of patients.

## Key Question 1b What is the comparative efficacy and effectiveness of AF catheter ablation versus different energy sources on short- (6–12 months) and long- (>12 months) term outcomes in the general adult and Medicare populations?

### Key Points

#### Cryoablation Versus Radiofrequency Ablation

##### Primary Outcomes

- Neither of the two RCTs identified reported on the primary clinical outcomes. One poor-quality observational study in patients with paroxysmal AF reported no statistical differences between treatments for all-cause mortality or TIA (>30 days) at 23 months (insufficient strength of evidence).

##### Intermediate Outcomes

###### Freedom From Recurrence and Reablation (>30 days)

- Short term (≤12 months):
  - Freedom from AF recurrence was less common following cryoballoon ablation compared with RFA across two trials, one in paroxysmal AF patients and one in a population that included those with different AF types, but differences failed to reach statistical significance in either. (insufficient strength of evidence).
  - Reablation was more common following cryoballoon ablation versus RFA in both trials but was statistically significant in only in the trial in those with paroxysmal AF (insufficient strength of evidence).
- Long term (>12 months)
  - No data from RCTs were identified
  - The proportions of patients in each group experiencing freedom from recurrence were similar in the cryoballoon ablation and RFA groups across two observational studies in those with paroxysmal AF (insufficient strength of evidence).

### Description of Included Studies

#### Randomized Controlled Trials

Two RCTs compared cryoballoon ablation with RFA reported outcome up to 12 months (range 3–29 months).74, 75 One trial included only patients with paroxysmal AF and the other included patient with both paroxysmal and persistent AF (mixed population). (Table 21) For both treatment arms of both studies, ablation was a second-line treatment, both studies reported a 3 month blanking period and no attrition was reported in either study. Study funding from National Institute of Health Carlos III, Madrid, Spain supported one study75 and the other was supported by CryoCath74 and authors in both trials reported receiving consulting and speaking fees from various industry groups.

Study sample sizes were small (50 and 60) and populations were predominantly male (80% and 78%) with similar mean ages (57 years). Hypertension was common in both trials (45% and 28%). Cryoballoon ablation was supplemented with focal cryoablation in one trial (which did not report on cross-over) if PV conduction persisted,75 but not in the other trial (which didn’t allow cross-over) which monitored cardiac electrical activity via an implantable cardiac monitor.

One trial was considered fair quality75 and the other poor quality.74 Neither study reported concealed treatment allocation and patients were not blinded. Information on randomization, and intention to treat analysis was not evident in the poor-quality trial.

Table 21 Patient characteristics and overview of study characteristics for RCTs comparing cryoballoon ablation with RFA in patients with AF

Author (Year) Therapy Sample Size | | Herrera Siklody (2012)74 Cryoballoon ablation (n=30) | Herrera Siklody (2012)74 RFA (n=30) | Perez-Castellano (2014)75 Cryoballoon ablation (n=25) | Perez-Castellano (2014)75 RFA (n=25)
Patient Demographics | Male, % (n) | 83.3 (25) | 76.7 (23) | 68 (17) | 88 (22)
Patient Demographics | Age (years); mean ± SD | 57 ± 8 | 56 ± 10 | 58 (range, 54–62) | 56 (range, 40–61)
Patient Demographics | Paroxysmal AF, % (n) | 70 (21) | 56.7 (17) | 100 (25) | 100 (25)
Patient Demographics | Persistent AF, % (n) | 30 (9) | 43.3 (13) | 0 (0) | 0 (0)
Patient Demographics | Mixed^*^, % (n) | 0 (0) | 0 (0) | 0 (0) | 0 (0)
Patient Demographics | AF duration (years); median (IQR) | 4.2 ± 2.7 | 5.6 ± 4.2 | NR | NR
Patient Demographics | Left atrial size (mm); mean ± SD | 41.4 ± 4.3 | 40 ± 5.5 | 42 (range, 39-47) | 42 (range, 38–45)
Patient Demographics | LVEF (%), mean ± SD | NR | NR | NR | NR
Patient Demographics | 1st/2nd line therapy | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line
Patient Demographics | Special population | None | None | None | None
Comorbidities, % (n) | Heart failure | NR | NR | NR | NR
Comorbidities, % (n) | Hypertension | 43.3 (13) | 46.7 (17) | 24 (6) | 32 (8)
Comorbidities, % (n) | Coronary artery disease | 10.0 (3) | 13.3 (4) | 16 (4) | 16 (4)
Comorbidities, % (n) | Cardiomyopathy | 6.7 (2) | 3.3 (1) | NR | NR
Comorbidities, % (n) | History of prior stroke | NR | NR | NR | NR
Comorbidities, % (n) | CHADS2 score, median (IQR) | NR | NR | NR | NR
Comorbidities, % (n) | Diabetes | NR | NR | 16 (4) | 8 (2)
Study Characteristics | Followup period (months) | 12 months (range, 3–29 months) | 12 months (range, 3–29 months) | 12 months | 12 months
Study Characteristics | Completed followup, % (n) | NR | NR | 100 (25) | 100 (25)
Study Characteristics | Blanking period (months) | 3 months | 3 months | 3 months | 3 months
Study Characteristics | Crossover, % (n) | NR | NR | 0 (0) | 0 (0)

AF = atrial fibrillation; BMI = body mass index; CHADS2 = Cardiac failure, Hypertension, Age, Diabetes, Stroke system; IQR = interquartile range; LVEF = left ventricular ejection fraction; NR = not reported; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation; SD = standard deviation.

* Mixed pattern was a combination of both types of AF (paroxysmal and persistent).

#### Comparative Observational Studies

Six comparative observational studies were also identified comparing cryoballoon ablation with RFA.76–81 Three studies reported outcomes during the periprocedural period only, with complete followup achieved in all patients,76, 79, 81 The remaining three studies reported longer-term outcomes with followup periods ranging from 14 to 28 months;77, 78, 80 and none of them reported attrition. Four studies only included patients with paroxysmal AF for whom ablation was a second-line therapy76, 77, 80, 81 (Table 22) and two studies included patients with either paroxysmal, persistent, or permanent AF who were treated as a second-line therapy in one study78 and as either a first and second-line therapy in the other (Table 23).79 Funding was reported by two of the four studies; one study received grant support from Basel University77 and several authors disclosed having received grants, speaking, and/or consulting fees from various industry groups and the other was funded by the British Heart Foundation and reported no conflicts of interest.78

The study sample sizes ranged from 124 to 3775. The cryoballoon ablation and RFA treatment groups were predominantly male and mean patient ages ranged from 57 to 63 years. All studies reported enrolling patients with comorbidities, particularly hypertension, but do not stratify results by population characteristics.

Patients received PVI either alone76, 77, 80, 81 or in combination with ablation at other sites (e.g., cavotricuspid isthmus, superior vena cava, linear lines and/or CFAE).78, 79 In one study, touchup ablation using RF energy was performed in 28 percent of cryoballoon ablation patients; only results for the subgroup of patients who received cryoballoon ablation only compared with RFA are included in this report. In all other studies, touchup ablation if necessary was performed with the same energy type or with RF energy in less than 20 percent of the cryoballoon ablation arm. Details of ablation and mapping techniques for each study are outline in Table H6 of the Appendix. Percent of patients who underwent touch-up ablation with the other energy source was reported in all studies, ranging from 0 to 28.2 percent in patients with paroxysmal AF,76, 77, 80, 81 and 11 to 23 percent in patients with paroxysmal, persistent, or permanent AF.78, 79

Two studies were considered to be fair quality,76, 77 and the other four poor quality.78–81 Five studies are of moderate sample size76–80 and one is a large study.81 Assessor blinding for primary clinical outcomes was not described in any of the studies, only three studies had acceptable attrition,76, 79, 81 three studies controlled for confounding,76, 77, 80 and four reported fully on prespecified outcomes.76–79 There were no studies in the Medicare population.

Table 22 Patient characteristics and overview of study characteristics for comparative observational studies comparing cryoballoon ablation with RFA in patients with paroxysmal atrial fibrillation

Author (Year) Therapy Sample Size | | Schmidt (2013) Retrospective81 Cryoballoon ablation (n=905) | Schmidt (2013) Retrospective81 RFA (n=2,870) | Mugnai (2014) Retrospective80 Cryoballoon ablation (n=136) | Mugnai (2014) Retrospective80 RFA (n=260) | Chierchia (2010) Prospective76 Cryoballoon ablation (n=46) | Chierchia (2010) Prospective76 RFA (n=87) | Knecht (2014) Prospective77 Cryoballoon ablation (n=71)^*^ | Knecht (2014) Prospective77 RFA (n=71)^*^
Patient Demographics | Male, % (n) | 64.3 (582) | 62.7 (1,800) | 72.1 (98) | 69.6 (181) | 78 (36) | 79 (69) | 74.7 (53) | 77.5 (55)
Patient Demographics | Age (years); mean ± SD | 63 (53–69) | 63 (54–69) | 57 ± 13.3 | 58.3 ± 8.7 | 56 ± 11 | 56 ± 9 | 58.6 ± 10.6 | 57.8 ± 11.2
Patient Demographics | Paroxysmal AF, % (n) | 100 (905) | 100 (2,870) | 100 (136) | 100 (260) | 100 (46) | 100 (87) | 100 (71) | 100 (71)
Patient Demographics | Persistent AF, % (n) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0)
Patient Demographics | Permanent AF, % (n) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0)
Patient Demographics | AF duration (years); mean ± SD | NR | NR | 25.1 ± 24 | 25.4 ± 37.1 | 3.3 ± 1.9 | 3.2 ± 1.7 | 67 ± 70 | 62 ± 70
Patient Demographics | Left atrial size (mm); mean ± SD | NR | NR | 41.6 ± 6.8 | 42.8 ± 6.7 | 41 ± 5 | 42 ± 5 | 39.5 ± 6.0 | 39.2 ± 5.3
Patient Demographics | LVEF (%), mean ± SD | [underlined: ≤40%:] 1.2 (11) | [underlined: ≤40%:] 2.4 (69) | [underlined: ≤40%:] 1.5 (2) | [underlined: ≤40%:] 2.3 (6) | 64 ± 6 | 64 ± 6 | 58.9 ± 6.6 | 58.8 ± 6.5
Patient Demographics | 1st/2nd line therapy | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line | 2^nd^ line
Patient Demographics | Special population | None | None | None | None | None | None | None | None
Comorbidities, % (n) | Hypertension | 57.8 (523) | 55.8 (1,601) | 25.7 (35) | 34.9 (90) | 24 (11) | 23 (20) | 43.7 (31) | 47.9 (34)
Comorbidities, % (n) | Coronary artery disease | 16.4 (149) | 16.4 (471) | 5.1 (7) | 9.6 (25) | NR | NR | 7.0 (5) | 9.9 (7)
Comorbidities, % (n) | Underlying heart disease | 32.5 (294) | 31.0 (890) | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | Kidney disease | 1.8 (16) | 2.7 (77) | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | Cardiomyopathy | 1.7 (15) | 2.2 (63) | 4.4 (6) | 5.0 (13) | NR | NR | NR | NR
Comorbidities, % (n) | Valvular disease (moderate/severe) | 3.0 (27) | 8.1 (232) | 1.5 (2) | 1.5 (4) | NR | NR | NR | NR
Comorbidities, % (n) | Prior stroke | 3.8 (34) | 5.5 (158) | 5.1 (7) | 7.6 (20) | NR | NR | NR | NR
Comorbidities, % (n) | Diabetes | 8.2 (74) | 7.2 (207) | 2.9 (4) | 6.9 (18) | NR | NR | 0 (0) | 0 (0)
Comorbidities, % (n) | BMI (kg/m2); mean ± SD | NR | NR | 26.2 ± 3.8 | 27.4 ± 4.8 | NR | NR | NR | NR
Comorbidities, % (n) | Dyslipidemia | NR | NR | 33.1 (45) | 24.4 (64) | NR | NR | NR | NR
Comorbidities, % (n) | Prior pacemaker or ICD implant | 5.0 (45) | 5.8 (167) | NR | NR | NR | NR | NR | NR
Comorbidities, % (n) | Previous ablation^†^ | NR | NR | 9.6 (13) | 18.1 (47) | NR | NR | NR | NR
Comorbidities, % (n) | Hypercholesterolemia | NR | NR | NR | NR | NR | NR | 38.0 (27) | 35.2 (25)
Comorbidities, % (n) | Smoking | NR | NR | NR | NR | NR | NR | 9.9 (7) | 9/9 (7
Study Characteristics | Followup period | Periprocedural | Periprocedural | 22.1 ± 14 | 24.0 ± 13.4 | Periprocedural | Periprocedural | 28 ± 15 | 28 ± 15
Study Characteristics | Completed followup, % (n) | 100 (905) | 100 (2,870) | NR | NR | 100 (46) | 100 (87) | NR | NR
Study Characteristics | Blanking period (months) | NR | NR | 3 months | 3 months | NR | NR | 3 months | 3 months
Study Characteristics | Touch-up with other energy source | 10.6 (96) | 0 (0) | 3.7 (5) | 0 (0) | 0 (0) | 0 (0) | 28.2 (20) | 0 (0)

AF = atrial fibrillation; BMI = body mass index; CHADS2 = Cardiac failure, Hypertension, Age, Diabetes, Stroke system; ICD = implantable cardioverter-defibrillator; IQR = interquartile range; LVEF = left ventricular ejection fraction; NR = not reported; RFA = radiofrequency catheter ablation; SD = standard deviation.

* In the cryoballoon ablation group, 28% (20/71) of patients received touchup ablation using a focal RF catheter. Authors report a propensity score-matched subgroup analysis in those patients who received cryoballoon only (n=51) vs. RFA (n=51); outcomes are reported in these subgroups only.

† Reported as previous cavotricuspid isthmus ablation or accessory pathway ablation.

Table 23 Patient characteristics and overview of study characteristics for comparative observational studies comparing cryoballoon ablation with RFA in patients with paroxysmal, persistent, or permanent atrial fibrillation

Author (Year) Therapy Sample Size | | Mandell (2013) Retrospective79 Cryoballoon ablation (n=62) | Mandell (2013) Retrospective79 RFA (n=62) | Kojodjojo (2010) Retrospective78 Cryoballoon ablation (n=124) | Kojodjojo (2010) Retrospective78 RFA (n=53)
Patient Demographics | Male, % (n) | 58.1 (36) | 74.2 (46) | 77 (96) | 77 (41)
Patient Demographics | Age (years); mean ± SD | 61 ± 8.8 | 60.4 ± 8.4 | 58.5 ± 9.4 | 59.3 ± 9.7
Patient Demographics | Paroxysmal AF, % (n) | 67.7 (42) | 54.8 (34) | 72.6 (90) | 100 (53)
Patient Demographics | Persistent AF, % (n) | 29.0 (18) | 43.5 (27) | 27.4 (34) | 0 (0)
Patient Demographics | Permanent AF, % (n) | 3.3 (2) | 1.6 (1) | 0 (0) | 0 (0)
Patient Demographics | AF duration (years); mean ± SD | NR | NR | 5.7 years | 6.0 ± 4.8
Patient Demographics | Left atrial size (mm); mean ± SD | NR (23.4% dilated) | NR (25.0% dilated) | 40.6 | 41.6 ± 6.5
Patient Demographics | LVEF (%), mean ± SD | NR | NR | 64.7 | 60.3 ± 7.3
Patient Demographics | 1st/2nd line therapy | Both (85.5% 1^st^ line) | Both (53.2% 1^st^ line) | 2^nd^ line | 2^nd^ line
Patient Demographics | Special population | None | None | None | None
Comorbidities, % (n) | Heart failure | 8.8 (5) | 12.9 (8) | NR | NR
Comorbidities, % (n) | Hypertension | 52.5 (33) | 64.5 (40) | 106 (62) | 26 (14)
Comorbidities, % (n) | Coronary artery disease | 16.1 (10/62) | 16.1 (10) | 6 (5) | 6 (3)
Comorbidities, % (n) | Obstructive sleep apnea | 9.7 (6) | 20.9 (13) | NR | NR
Comorbidities, % (n) | Valvular disease (moderate/severe) | Mitral: 14.5 (9) Aortic: 3.2 (2) Other: 0 (0) | Mitral: 4.8 (3) Aortic: 0 (0) Other: 3.2 (2) | NR | NR
Comorbidities, % (n) | LV hypertrophy | 1.7 (1) | 9.7 (6) | NR | NR
Comorbidities, % (n) | BMI (kg/m2); mean ± SD | 30.5 ± 7.2 | 31.3 ± 7.2 | NR | NR
Study Characteristics | Followup period | Periprocedural | Periprocedural | 13.3 ± 7.4 months | 15.6 ± 7.4 months
Study Characteristics | Completed followup, % (n) | 100 (62) | 100 (62) | NR | NR
Study Characteristics | Blanking period (months) | None used | None used | 3 months | 3 months
Study Characteristics | Touch-up with other energy source | 11 (7) | 0 (0) | 23 (28) | 0 (0)

AF = atrial fibrillation; BMI = body mass index; CHADS2 = Cardiac failure, Hypertension, Age, Diabetes, Stroke system; ICD = implantable cardioverter-defibrillator; IQR = interquartile range; LVEF = left ventricular ejection fraction; NR = not reported; RFA = radiofrequency catheter ablation; SD = standard deviation.

### Detailed Synthesis

#### Primary Outcomes

None of the primary outcomes of interest (mortality, stroke, congestive heart failure, health-related quality of life, etc.) were reported by any of the RCTs. One poor-quality observational study80 in people with paroxysmal AF reported all-cause mortality greater than 30 days of 1.2 percent (3/260) in the RFA arm versus none (0/136) in the cryoballoon ablation arm and TIA of 0.4 percent (1/260) and 0.7 percent (1/136) in the RFA and cryoballoon ablation patients, respectively (Table 24).

#### Intermediate Outcomes

##### Freedom From Recurrence of Atrial Arrhythmia

Freedom from AF recurrence was reported in both RCTs and was less common in those receiving cryoballoon ablation (48% and 68%) versus RFA (66.7% and 86.7%) but differences between treatments failed to reach statistical significance in either trial (Table 25).74, 75 In those with paroxysmal AF 48 percent of the cryoballoon group versus 68 percent of the RFA group were free from recurrence at 12 months.75 The trial that included patients with any AF type reported 66.7 percent of cryoballoon ablation versus 86.7 percent RFA recipients were free from recurrence.74

Across three observational studies (one fair-, two poor-quality), in paroxysmal AF patients, no statistical differences between cryoballoon ablation and RFA for freedom from recurrence were seen at 12 months,78 23^80^ or 28 months77; the proportions of patients in each group experiencing freedom from recurrence were similar (Table 24). One poor-quality study reported no significant differences between treatment groups based on survival analysis at any time point up to 18 months.78

##### Reablation

Reablation for AF only was more common following cryoballoon ablation in both RCTs at 12 months. In the fair-quality trial of paroxysmal AF, a significant difference was seen between cryoballoon ablation (24%) and RFA (0%) (RR 0.22, 95% CI 0.07 to 0.37, p=0.01).75 In the second poor-quality trial in people with any AF type, the difference between groups failed to reach statistical significance (cryoballoon ablation 30% vs. RFA 13.3%; RR 2.25, 95% CI 0.78 to 6.51; p=0.12)74 as did reablation for any arrhythmia as reported by this same trial (cryoballoon ablation 30% vs. RFA 20%; RR 1.5, 0.61 to 3.7, p=0.37)74 (Table 25).

Conversely, repeat ablation was more common in the RFA arm (23%) as compared to the cryoballoon ablation arm (14%) after an overall mean followup period of 14 months in one poor-quality observational study of a mixed AF population but was not statistically significant.78 Of note, the patients who received RFA were followed for a longer period of time than those who received cryoballoon ablation, 15.6 ± 7.4 months versus 13.3 ± 7.4 months (Table 24).

##### Atrial Flutter

There were no statistical differences between cryoballoon and RFA in either trial, however, the trial of paroxysmal AF (fair quality) reported a higher frequency after cryoballoon ablation versus RFA (16% versus 4%)75 than the other poor-quality trial in a mixed AF population (0% versus 6.7%)74 (Table 25).

##### AF burden

AF burden in patients who experienced AF recurrence after ablation (n=21) was reported in one fair-quality trial of paroxysmal AF.75 Although there was no statistical difference between cryoballoon and RFA in the median number of AF episodes per month (7.3 for cryoballoon versus 0.7 for RFA) or in the maximum duration of AF episodes (12 versus 4.4 hours), the number of hours per month and percent of time spent in AF were significantly different (Table 25).

##### Complete Isolation of Pulmonary Veins

One poor-quality retrospective comparative observational study of a mixed AF population reported no difference between cryoballoon ablation and RFA treatment groups in terms of the percentage of patients who had treatment failure (96.2% vs. 93.4%) (N=124), which was defined as complete isolation of all pulmonary veins as evidenced by complete entrance and exit block.79

##### Effect on Coagulation and Inflammatory Biomarkers

One poor-quality RCT focused on comparing cryoballoon ablation with RFA with respect to procoagulant microparticles, platelet activation and inflammatory biomarkers.74 Both treatments were similar with respect to the release of high-sensitivity troponin T, shedding of procoagulant microparticles, and platelet activation at 24 and 48 hours. High sensitivity C-reactive protein tended toward a higher peak value after 48 hours post RFA (28.6 ± 22.7 mg/L vs. cryoablation 20.5 ± 23.3 mg/L, p=0.175), with no statistically significant differences after correction for repeated measurements.

Table 24 Primary and intermediate effectiveness outcomes for comparative observational studies comparing cryoballoon ablation with RFA

Outcome | | AF Type (1^st^/2^nd^ line therapy) | Study | Followup | Cryoballoon ablation % (n/N) | RFA % (n/N) | p- value
Primary Outcomes^*^ | Mortality (all-cause) >30 days | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Mean 23 ± 13.4 months | 0% (0/136) | 1.2% (3/260)^†^ | NR
Primary Outcomes^*^ | TIA >30 days | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Mean 23 ± 13.4 months | 0.7% (1/136)^‡^ | 0.4% (1/260)^‡^ | NR
Intermediate Outcomes | Freedom from recurrence (any arrhythmia) | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Mean 23 ± 13.4 months | 63.2% (86/136) | 57.3% (149/260) | 0.25
Intermediate Outcomes | Freedom from recurrence (any arrhythmia) | Paroxysmal (2^nd^ line) | Knecht 2014^77^ | Mean 28 ± 15 months | 54.9% (28/51)^§^ | 54.9% (28/51)^§^ | 0.81
Intermediate Outcomes | Freedom from recurrence (any arrhythmia) | Paroxysmal (2^nd^ line) | Kojodjojo 2010^78^ ** | 12 months | 76.7% (79/90)^**^ | 71.7% (38/53)^**^ | NS
Intermediate Outcomes | Repeat ablation for recurrent AF | Mixed (2^nd^ line) | Kojodjojo 2010^78^ | Mean 14 months | 13.7% (17/124) | 22.6% (12/53) | NR

AF = atrial fibrillation; NA = not applicable; NR = not reported; NS = not significant; RFA = radiofrequency ablation; TIA = transient ischemic attack.

* Mortality and TIA had to occur at a time point >30 days (or timing NR) to be considered an effectiveness outcome. TIA was not defined further in the study.

† Spontaneous massive intracerebral hemorrhage (after 3 months); cardiogenic shock and sepsis in hypertrophic cardiomyopathy with severely reduced ejection fraction (33%) (at 7 months); and severe endocranial hypertension secondary to cerebral glioblastoma (at 9 months).

‡ TIAs occurred at 5 months (RFA) and 6 months (Cryoablation). One patient receiving RFA had 2 TIAs.

§ Reported in a subset of 51 patient subset of propensity score-matched dataset comparing patients who underwent pulmonary vein isolation using cryoballoon ablation only and RFA.

** Kojodjojo 2010 included both paroxysmal (n=90) and persistent (n=34) patients in the cryoballoon ablation group. However, for the outcome freedom from recurrence, authors compared only the 90 paroxysmal patients with the RFA group (all 53 paroxysmal); therefore, for this outcome only, Kojodjojo 2010 is listed as “AF Type” paroxysmal (versus mixed for repeat ablation).

Table 25 Intermediate efficacy outcomes for RCTs comparing cryoballoon ablation with RFA

Outcome | AF Type (1^st^/2^nd^ line therapy) | Study | Followup | [underlined: Cryoablation] % (n/N) | [underlined: RFA] % (n/N) | Effect size RR (95% CI)^*^
Freedom From Recurrence (AF only) | Paroxysmal (2^nd^ line) | Perez Castellano 2014^75^ | 12 months | 48.0% (12/25) | 68.0% (17/25) | RR 0.71 (0.43, 1.14) p=0.15
Freedom From Recurrence (AF only) | Mixed (2^nd^ line) | Herrera Siklody 2012^74^ | 12 months | 66.7% (20/30)^*^ | 86.7% (26/30) | RR 1.1 (0.76, 1.5) p=0.68
Reablation (AF only) | Paroxysmal (2^nd^ line) | Perez Castellano 2014^75^ | 12 months | 24.0% (6/25) | 0% (0/25) | RR 0.22 (0.07, 0.37) p=0.01
Reablation (AF only) | Mixed (2^nd^ line) | Herrera Siklody 2012^74^ | 12 months | 30.0% (9/30) | 13.3% (4/30) | RR 2.25 (0.78, 6.51) p=0.12
Reablation (any arrhythmia) | Mixed (2^nd^ line) | Herrera Siklody 2012^74^ | 12 months | 30.0% (9/30) | 20.0% (6/30)^†^ | RR 1.5 (0.61, 3,7) p=0.37
Atrial Flutter | Paroxysmal (2^nd^ line) | Perez Castellano 2014^75^ | 12 months | 16.0% (4/25)^‡^ | 4.0% (1/25)^‡^ | RR 4.0 (0.48, 33.3) p=0.17
Atrial Flutter | Mixed (2^nd^ line) | Herrera Siklody 2012^74^ | 12 months | 0% (0/30) | 6.7% (2/30) | RR incalculable p=0.49
AF Burden (median IQR): Number of AF episodes per month | Paroxysmal (2^nd^ line) | Perez Castellano 2014^75^ | 12 months | [underlined: n=13]^§^ 7.3 (0.2–381) | [underlined: n=8]^§^ 0.7 (0.1–2.2) | p=0.07
AF Burden (median IQR): Time in AF (hours/month) | Paroxysmal (2^nd^ line) | Perez Castellano 2014^75^ | 12 months | [underlined: n=13]^§^ 44.6 (1.4–197.5) | [underlined: n=8]^§^ 1.4(0.2–5.4) | p=0.02
AF Burden (median IQR): Time in AF (%) | Paroxysmal (2^nd^ line) | Perez Castellano 2014^75^ | 12 months | [underlined: n=13]^§^ 0.06 (0.002–0.27) | [underlined: n=8]^§^ 0.002 (0.001–0.01) | p=0.02
AF Burden (median IQR): Maximum duration of AF episodes (hours) | Paroxysmal (2^nd^ line) | Perez Castellano 2014^75^ | 12 months | [underlined: n=13]^§^ 12 (4.8–23.6) | [underlined: n=8]^§^ 4.4(1.4–23.2) | p=0.38

AADs = antiarrhythmic drugs; AF = atrial fibrillation; IQR = interquartile range; NR = not reported; RFA = radiofrequency ablation; RR = risk ratio.

* Risk ratios, 95% CI and p-values (except for AF burden) were calculated using Stata. Risk ratio was chosen (as opposed to odds ratio) because it may be a more appropriate measure of effect size given that this is a frequent event.

* Of the 11 patients reported to have an AF recurrence in the cryoablation group, one experienced AV nodal reentrant tachycardia and underwent reablation 2 months after the index procedure. For the purposes of this report, any recurrence or reablation occurring with 3 months is considered an adverse event; thus, this patient was not counted for either freedom from recurrence or reablation as a secondary efficacy outcome.

† Two patients underwent reablation for atrial flutter.

‡ All patients with atrial flutter recurrence also had AF recurrence.

§ AF burden in patients with AF recurrences after ablation.

## Key Question 2a What are the comparative short- and long-term complications and harms (e.g., periprocedural or device-related harms) associated with AF catheter ablation versus medical therapy in the general adult and Medicare populations?

### Key Points

#### Radiofrequency Ablation Versus Medical Therapy

##### Mortality (all-cause) (within 30 days)

- Overall: The 30-day mortality risk was similarly low following RFA versus medical therapy based on data from five RCTs of patients with paroxysmal or persistent AF.
- Paroxysmal AF: There was low risk of this event in both treatment groups based on three RCTs (RFA: 0% to 0.7%; medical therapy: 0%) (low strength of evidence).
- Persistent AF: There was low risk of all-cause mortality following RFA and medical therapy based on data from two RCTs (RFA: 0%; medical therapy: 0% to 4.2% [1/24]) (low strength of evidence). One prospective cohort study of the subpopulation of patients 65 years and older (Medicare population) reported low risk in both treatment groups (insufficient strength of evidence).

##### Stroke (any type) (within 30 days)

- Overall: The 30-day stroke risk was low following RFA and medical therapy based on data from eight RCTs (RFA: 0% to 4.8%; medical therapy: 0%).
- Paroxysmal AF: There was low risk in both groups as reported by three RCTs (RFA: 0% to 0.7%; medical therapy: 0%) (low strength of evidence).
- Persistent AF: The risk was low in both groups based on data from three RCTs (RFA: 0% to 4.8%; medical therapy: 0%) (low strength of evidence). In the subpopulation of patients 65 years and older (Medicare population) a single observational prospective cohort study reported higher risk following RFA versus medical therapy (insufficient strength of evidence).
- Mixed: There was low risk in both groups based on data from two RCTs (RFA: 0% to 1.5%; medical therapy: 0%) (low strength of evidence). One observational retrospective cohort study also reported low risk in both treatment groups (insufficient strength of evidence).

##### Atrial Fibrillation (within 3 months)

- Paroxysmal AF: The 3-month AF risk was similarly low across RFA and medical therapy groups based on data from two RCTs (pooled RR 0.67, 95% CI 0.40 to 1.11) (low strength of evidence).
- Persistent AF: The 2- to 3-month risk of AF recurrence was lower following RFA versus medical therapy based on data from three RCTs (pooled RR, 0.18, 95% CI 0.11 to 0.30).
- Mixed: Comparative data not reported (insufficient strength of evidence).

##### Cardiac Tamponade

- Paroxysmal AF: The incidence of cardiac tamponade following RFA was low based on data from four RCTs (512 patients total) (pooled risk 1.7%; 95% CI 0.8 to 2.6) (low strength of evidence).
- Persistent AF: Pooled data from three small RCTs of 73 patients total suggested the incidence of cardiac tamponade following RFA was 5.5 percent (95% CI 2.1 to 13.7), while one observational comparative study on the subset of patients aged 65 years and older (Medicare population) reported no events (insufficient strength of evidence).

##### Pericardial Effusion

- Overall: The incidence of pericardial effusion following RFA was low based on data from five RCTs (range, 0.5% to 0.9 %).
- Paroxysmal AF: The incidence of pericardial effusion following RFA was low based on data from four RCTs (pooled risk 0.6%, 95% CI 0.2 to 1.8) (low strength of evidence).
- Persistent AF; Mixed AF: One RCT each reported a low risk following RFA (insufficient strength of evidence).

##### Pulmonary Vein Stenosis

- Paroxysmal AF: The incidence of pulmonary vein stenosis following RFA was low based on data from five RCTs (range, 0% to 3.1%) (low strength of evidence). One nonrandomized comparative study reported zero cases (insufficient strength of evidence).
- Persistent AF: The incidence of pulmonary vein stenosis following RFA was low based on data from two RCTs (range, 0% to 0.9%) (low strength of evidence). For the subset of patients aged 65 years and older (Medicare population), one nonrandomized comparative study reported no cases (insufficient strength of evidence).
- Mixed: There were no cases following RFA as reported by one RCT (low strength of evidence). The risk of pulmonary vein stenosis was higher in one nonrandomized comparative study (insufficient strength of evidence).

##### Drug Intolerance Leading to Discontinuation

- Paroxysmal AF: Overall, 5 to 23 percent of patients randomized to medical therapy discontinued antiarrhythmic drugs due to adverse events or intolerance (2 RCTs) (low strength of evidence). Due to limited duration and/or usage of medical therapy in the RFA group it was difficult to make comparative conclusions.
- Persistent AF: There was no evidence from RCTs. One nonrandomized comparative study of Medicare-aged patients reported this event in fewer patients in the RFA versus the medical therapy groups (insufficient strength of evidence).
- Mixed: One RCT reported similar risk between groups (insufficient strength of evidence).

#### Cryoablation Versus Medical Therapy

##### Mortality (all-cause), Stroke (any type) (within 30 days)

- Mixed: No deaths occurred in either treatment group, and the 30-day stroke risk was low in both treatment groups (cryoballoon ablation: 0.6%; medical therapy: 1.2%) based on data from one RCT (insufficient strength of evidence).

##### AF recurrence (within 3 months)

- Mixed: Over half of cryoablation patients (51.5%) experienced recurrence of AF within 3 months of treatment based on data from one RCT; no data were reported for the control group (insufficient strength of evidence).

##### Cardiac Tamponade

- Mixed: One RCT reported low incidence of cardiac tamponade following cryoballoon ablation (0.9% for both) (insufficient strength of evidence).

##### Pulmonary Vein Stenosis

- Mixed: One RCT reported low incidence of pulmonary vein stenosis following cryoablation (0.9%) (insufficient strength of evidence).

##### Atrial Fibrillation (within 3 months), Pericardial Effusion, Drug Intolerance Leading to Discontinuation

- Mixed: No data reported.

### Radiofrequency Ablation Versus Medical Therapy

#### Description of Included Studies

##### Randomized Controlled Trials

All thirteen RCTs comparing RFA with medical therapy that were included in Key Question 1a reported adverse events.35–47, 83 See Key Question 1a as well as the detailed demographics tables for general study characteristics (Appendix E, Tables E1–E3, E7–E9). There was substantial crossover (37.0%–87.9%) from medical therapy to RFA in six trials35, 42–45, 47, 83 and two trials reported lower crossover rates of 9.4 percent38 and 3.8 percent.39 There was also crossover from RFA to medical therapy in seven RCTs (0%–9.4%).35, 38, 41, 42, 44, 46, 47, 83 Adverse events attributable to either ablation or medical therapy were reported on an as-treated basis and thus data includes crossover patients.

##### Comparative Observational Studies

Seven comparative observational studies comparing RFA with medical therapy reported adverse events. See Key Question 1a as well as the detailed demographics tables for general study characteristics (Appendix E, Table E4–E6, E10–E12). Four of the studies were fair-quality,48–50, 52 and three were poor quality.51, 53, 54 Three included only paroxysmal AF patients,49, 52, 54 one included only persistent AF patients,48 two included a mix of AF types,51, 53 and one did not specify AF type.50 The study of persistent AF patients reported that 1.9 percent (5/259) medical therapy patients crossed over to RFA due to AF/AT recurrence, while 9.2 percent (14/153) of RFA patients experienced recurrence and were treated with medical therapy.48 Two studies were applicable to the Medicare population: one only included elderly patients (mean age, 75.6 years),48 while another included patients with a mean age of 67 years.53

##### Case Series

Sixteen case series and one meta-analysis of case series specifically designed to evaluate the incidence of adverse events following catheter ablation were included: four prospective57, 58, 64, 68 and two retrospective63, 71 case-series; two prospective, multicenter registries;55, 60 two prospective database studies (one single-center,59 one multicenter56); one survey of eighteen electrophysiological centers;69 five administrative database studies,61, 62, 65, 67, 70 one of which was in Medicare beneficiaries65 and one meta-analysis of case series reporting on AF recurrence.66 Seven studies included paroxysmal, persistent and permanent AF patients,55–59, 66, 71 two included only paroxysmal and persistent,60, 64 and six did (or could) not report the type of AF in their populations.61–63, 65, 67–70 Sample sizes ranged from 1000 to 15,423 patients, with two studies reporting events per the number of procedures only (1190 and 93,801).59, 62 Followup periods varied across studies and included inpatient,61, 62, 66 periprocedural,57, 58, 63 7 days or less,67, 69 30 days or less,55, 59, 60, 65 and 3 months or less.56, 64 Ablation was performed using RF energy exclusively in twelve studies,55–59, 62–64, 66–68, 71 and a mix of energy sources (i.e., RF, cryoballoon) in two;60, 61 three studies did not report the type of energy used.65, 69, 70

#### Detailed Synthesis

##### Major Adverse Events

###### Mortality (cardiovascular) (within 30 days)

Five fair-quality small RCTs (range, 50–286 patients) comparing RFA with medical therapy reported mortality caused by cardiovascular events that occurred within 30 days of treatment.35, 37, 41, 42, 47 Three trials included only paroxysmal AF patients,35, 42, 47 while two included only persistent AF patients.37, 41 Overall, the risk of mortality from cardiovascular causes following RFA versus medical therapy was low (range, 0%–0.7% vs. 0%–4.2% of patients). Specifically only one death occurred in each treatment group: one paroxysmal AF patient in the ablation group died of a procedure-related cerebral stroke35 and one persistent AF patient with heart failure treated with medical therapy experienced sudden cardiac death37 (Table 26).

No comparative observational studies comparing RFA with medical therapy reported cardiovascular mortality within 30 days of treatment.

Mortality due to cardiovascular causes within 30 days of ablation was not reported in any of the case series.

###### Mortality (all-cause) (within 30 days)

Five fair-quality RCTs comparing RFA with medical therapy reported all-cause mortality occurring within 30 days of treatment.35, 37, 41, 42, 47 These trials were small, enrolling between 50 and 286 patients. Three trials included only paroxysmal AF patients,35, 42, 47 and two included only persistent AF patients.37, 41 Overall, the risk of mortality following RFA versus medical therapy was low (range, 0%–0.7% vs. 0%–4.5% of patients), with only one death occurring in each treatment group (Table 26). Details on the causes of death are noted in the previous section (cardiovascular mortality).

One fair-quality prospective comparative observational study of 412 persistent AF patients with a mean age of 75 (i.e., Medicare population) treated with RFA versus medical therapy similarly reported low rates of all-cause mortality (0% vs. 0.4%, respectively) (Table 27).48 The cause of death was not reported.

Across eleven case series, all-cause mortality within 30 days of ablation was reported in: 0 to 0.4 percent of RFA patients (N=1000–5947),55–57, 64, 67 0.4 percent of RFA procedures (1190–93,801 procedures),59, 62 and 0.1 to 0.8 percent of patients who underwent procedures using a variety of energy sources (N=1273–15,423) (Appendix H, Table H4).60, 61, 65, 70

###### Stroke (any type) (within 30 days)

Eight RCTs reported stroke within 30 days following RFA versus the initiation of medical therapy.35–37, 40–42, 45, 46 One trial was considered good quality,45 and the remaining seven were fair quality.35–37, 40–42, 46 Each trial enrolled between 40 and 286 patients. Overall, there was no difference in 30-day stroke risk between treatment groups in any study, with stroke reported in 0 to 4.8 percent of RFA patients per study and in 0 percent of medical therapy patients (Table 26). In total, four RFA patients experienced a stroke: one paroxysmal AF patient had a peri-procedural cerebral stroke (that resulted in death),35 one patient in another study of heart failure patients experienced a procedural stroke and withdrew from the study,37 and one person in a study of patients with advanced heart failure and persistent AF had a stroke 6 days post-ablation and withdrew from the study,40 and one patient in a mixed AF population study had a stroke during left atrium ablation.45

Two comparative observational studies48, 51 reported on this outcome: one fair-quality prospective of 412 persistent AF patients with a mean age of 75 years (i.e., Medicare population),48 and one poor-quality retrospective study of a mixed AF population.51 While the fair-quality Medicare population study found a higher risk of 30-day stroke following RFA versus medical therapy (2.6% vs. 0.4%, p=0.0462) (N=411),48 there was no difference in the occurrence of stroke within the first 30 days of treatment initiation between treatment groups in the low-quality study (1.2% vs. 1.2%; N=170) (Table 27).51

Across eight case series and one meta-analysis of case series, stroke within 30 days of ablation was reported in: 0.08 percent to 0.71 percent of RFA patients (N=1000–7217),55, 57, 64, 66–68 0.8 percent of 1190 RFA procedures,59 and in 0.2 percent to 0.6 percent of patients who underwent procedures using a variety of energy sources (N=4156–6207) (Appendix H, Table H4).61, 70

###### Myocardial Infarction (within 30 days)

One RCT of 159 paroxysmal AF patients reported no cases of myocardial infarction within 30 days of treatment initiation in either group (Table 26).47

One prospective fair-quality cohort study of 412 persistent AF patients with a mean age of 75 years (i.e., Medicare population) reported no difference in 30-day myocardial infarction between the RFA and medical therapy groups (1.3% vs. 0%; N=412 patients total) (Table 27).48

Across three case series, myocardial infarction within 30 days of ablation was reported in: 0.30 percent of 5947 RFA patients,67 0.37 percent of 93,801 RFA procedures,62 and in 0.31 percent of patients who underwent procedures using a variety of energy sources (N=15,423) (Appendix H, Table H4).65

###### Transient Ischemic Attack (within 30 days)

Six fair-quality RCTs reported TIA within 30 days of treatment (Table 26).36, 41, 42, 44, 46, 47 Across the four RCTs of paroxysmal AF patients (range, 70–198 patients), TIA occurred in 0 to 1 percent of patients in the RFA group and in 0 percent of medical therapy patients.42, 44, 46, 47 One small study of persistent AF patients41 and one small study of a mixed population of patients36 each reported no instances of 30-day TIA in either treatment group.

One prospective fair-quality cohort study of 412 persistent AF patients with a mean age of 75 (i.e., Medicare population) reported similar risk of 30-day TIA following RFA versus medical therapy (1.3% vs. 0.4%) (Table 27).48

Across eight case series, TIA within 30 days of ablation was reported in: 0.1 percent to 0.6 percent of RFA patients (N=1000–5947),55–57, 64, 67, 68 0.3 percent of 1190 RFA procedures,59 and in 0.07 percent of patients who underwent procedures using a variety of energy sources (N=4156) (Appendix H, Table H4).61

Across four case series, stroke or TIA within 30 days of ablation was reported in: 0.4 percent to 1.0 percent of 1506 to 93,801 RFA procedures62, 71 and in 0.7 to 0.8 percent of patients who underwent procedures using a variety of energy sources (N=1273–15,423) (Appendix H, Table H4).60, 65

###### Other Embolic Events (within 30 days)

One fair-quality RCT of 159 paroxysmal AF patients reported no cases of thromboembolic events within 30 days of treatment in either group (Table 26).47

Two fair-quality prospective cohort studies also reported on this outcome. While one study of 412 elderly patients (mean age, 75 years, Medicare population) with persistent AF reported no other instances of 30-day embolic events following either RFA or initiation of medical therapy,48 one study of 166 paroxysmal AF patients reported that no RFA patients and three AAD patients experienced thromboembolic events (0% vs. 3.6%, respectively) (Table 27).52 This difference was not statistically meaningful.

Two case series reported other embolic events within 30 days of ablation in 0.08 percent to 0.70 percent of RFA patients (N=1294–5947); specifically, there was one case of mesenteric embolism (Appendix H, Table H4).64, 67

###### Major Bleeding, Hemorrhage, or Transfusion (within 30 days)

There was no difference in the risk of 30-day major bleeding, hemorrhage, or transfusion between treatment groups as reported by two fair-quality RCTs (range, 5.7%–6.4% vs. 1.9%–5.7%; N=137 total) (Table 26).46, 47 One study enrolled paroxysmal AF patients46 and the other enrolled a mix of paroxysmal and persistent AF patients.47

One fair-quality prospective observational study of 412 persistent AF patients with a mean age of 75 (i.e., Medicare population) reported no cases of this outcome following RFA versus medical therapy (N=412 patients) (Table 27).48

Across five case series, major bleeding, hemorrhage, or transfusion within 30 days of ablation was reported in: 3.7 percent of 5947 RFA patients,67 0.07 to 4.0 percent of 1190 to 93,801 RFA procedures,59, 62, 71 and 2.1 percent of 6207 patients undergoing ablation using a variety of energy sources70 (Appendix H, Table H4).

###### Heart Failure (within 30 days)

Two fair-quality RCTs reported heart failure within 30 days of treatment initiation.40, 47 There was no difference between treatment groups in the risk of heart failure in one trial of 159 paroxysmal AF patients (1.0 % vs. 0%)47 or in the development of worsening heart failure in one trial of 40 persistent AF patients with advanced heart failure (14.3% vs. 0%) (Table 26).40 In the latter trial, two patients were treated with intravenous diuretic before discharge, and one patient required readmission for treatment.

One fair-quality prospective observational study of 412 persistent AF patients with a mean age of 75 (i.e., Medicare population) reported no instances of 30-day heart failure (Table 27).48

Heart failure within 30 days of ablation was not reported in any of the case series.

###### Arrhythmia (within 3 months)

###### Atrial Fibrillation

Atrial fibrillation was reported to recur within the first 3 months following initiation of treatment in 11.1 to 47.6 percent of RFA patients (6 RCTs)35, 37, 40, 43, 44, 46 and in 37.7 to 100 percent of medical therapy patients (4 RCTs) (Table 26).35, 37, 43, 46 Although the trend suggests that 3-month AF recurrence was more frequent in the medical therapy group, only four of the six RCTs reported comparative data for the RFA versus medical therapy groups, all of which were fair quality.35, 37, 43, 46 Of the two studies of paroxysmal AF patients reporting data for both groups, the pooled estimate suggests no difference between treatment groups (pooled RR 0.74, 95% CI 0.40 to 1.10) (Figure 8). While one found a significantly lower risk of 2-month AF recurrence in RFA patients (RR 0.50, 95% CI 0.27 to 0.95; N=70),46 the other found no difference between treatment groups in AF recurrence within the first 3 months (RR 0.82, 95% CI 0.59 to 1.13; N=286).35 Both of these studies were treating patients with a first-line therapy for paroxysmal AF, and in neither study administered medical therapy to RFA patients (unless crossover occurred). One trial did not allow crossover until much later (≥12 months),46 and the other did not restrict the timing of crossover.35 In the latter RCT, 9 percent of RFA and 37 percent of medical therapy patients crossed over. In contrast, pooled data from the two trials of persistent AF patients reporting for both groups found that the risk of 2- to 3-month AF recurrence was significantly lower in RFA patients (pooled RR 0.18, 95% CI 0.11 to 0.30; N=146) (Figure 8).37, 43 Of note, both of these trials were in heart failure patients.

One poor-quality observational retrospective cohort study of a mixed population of AF patients reported that 46 percent (39/85) of RFA patients had recurrence of AF within the first 2 months, however, no data were reported for the medical therapy group (Table 27).51

AF within 3 months of ablation was not reported in any of the included case series.

Figure 8 Profile likelihood model meta-analysis of AF recurrence within the first 3 months of followup in RCTs comparing RFA with medical therapy in patients with paroxysmal AF

AF = atrial fibrillation; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation; RR = relative risk.

Figure 8. This figure is a forest plot that displays atrial fibrillation (AF) recurrence within the first 3 months following radiofrequency ablation (RFA) compared with medical therapy as reported by four randomized controlled trials (RCTs). From the two trials of paroxysmal AF patients, the pooled estimate suggests no difference between treatment groups (pooled relative risk [RR] 0.74, 95% confidence interval [CI] 0.40 to 1.10). In contrast, pooled data from the two trials of persistent AF patients found that the risk of 2- to 3-month AF recurrence was significantly lower in RFA patients (pooled RR 0.18, 95% CI 0.11 to 0.30). Of note, both of these trials were in heart failure patients.

###### Other Types of Arrhythmia (within 3 months)

Data from three fair-quality RCTs suggested that atrial flutter within the first 3 months of treatment initiation occurred in a small percentage of patients, with no difference between RFA and medical therapy treatment groups in any trial (0%–5.2% vs. 0%–1.5%) (125 to 198 patients per study) (Table 26).42–44

Two fair-quality RCTs reported that, compared to those in the RFA groups, nearly twice as many patients in the medical therapy experienced atrial fibrillation or atrial flutter within the first 5 weeks to 3 months.36, 41 In the trial of 141 persistent AF patients the difference between groups was significant (29.6% vs. 54.2%),41 while the difference between groups in the smaller study of 70 mixed AF patients did not (8.6% vs. 14.3%) (Table 26).36

Regarding bradycardia, one fair-quality RCT of 125 paroxysmal patients reported no difference between RFA and medical therapy groups (1.5% vs. 0%),42 while another fair-quality RCT of 198 paroxysmal AF patients reported significantly lower risk of bradycardia following RFA versus medical therapy (0% vs. 15.2%, p<0.001) (Table 26).83 This latter RCT also reported lower rates of tachycardia following RFA versus medical therapy (9.1% vs. 36.4%; RR 0.25, 95% CI 0.13 to 0.49).44

Arrhythmias not clearly defined that occurred within the first 3 months as reported by RCTs are listed in Table 26.

One comparative observational study reported no cases of torsade de points in either treatment group (Table 27).49

Arrhythmias within 3 months of ablation were not reported in any of the included case series.

###### Ablation-Related Adverse Events

###### Cardiac Tamponade

Seven fair-quality RCTs assessed the risk of cardiac tamponade in patients who were randomized to RFA or who received RFA after crossover from the medical therapy group.35, 37–40, 42, 47 Overall, the risk of cardiac tamponade ranged from 0 to 9.5 percent (2/21) (range, 21–194 patients per study) (Figure 9, Table 26). In the four trials of paroxysmal AF patients, cardiac tamponade occurred in 0 to 4.5 percent (4/89) of patients (range, 89–194 patients per study), with a pooled estimate of 1.7 percent (95% CI 0.8 to 3.6).35, 38, 42, 47 In the three small trials of persistent AF patients, procedural cardiac tamponade occurred in 4 percent (1/26) to 10 percent (2/21 in both trials reporting) of patients, with a pooled estimate of 5.4 percent (95% CI 2.1 to 13.7).37, 39, 40 In total, 13 patients from these RCTs developed cardiac tamponade, and no long-term sequelae were attributed to this complication.

Two fair-quality prospective observational studies reported no instances of cardiac tamponade following RFA (Table 27).48, 52 One trial enrolled paroxysmal AF patients (N=85),52 and the other enrolled elderly (mean age 75 years, Medicare population) patients with persistent AF (N=158).48

Across eight case series and one meta-analysis of case series, cardiac tamponade was reported in: 0.6 to 1.3 percent of RFA patients (N=1000–7217),55–57, 66 1.1 percent of 1190 RFA procedures,59 2.5 to 6.7 percent of patients who underwent procedures using a variety of energy sources (N=1273–6207),60, 61, 70 and 0.8 percent of 34,943 procedures performed with a variety of energy sources (Appendix H, Table H4).69

Figure 9 Risk of cardiac tamponade following RFA from RCTs in patients with paroxysmal or persistent AF

AF = atrial fibrillation; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation.

*Patients with heart failure.

Figure 9. This figure is a bar graph that displays the percentage of patients who had cardiac tamponade following radiofrequency ablation (RFA) as reported by seven fair-quality randomized controlled trials (RCTs). Overall, the risk of cardiac tamponade ranged from 0 to 9.5 percent. In the four trials of paroxysmal AF patients, cardiac tamponade occurred in 0 to 4.5 percent of patients over followup periods ranging from 1 to 24 months, with a pooled estimate of 1.7 percent (95% confidence interval [CI] 0.8 to 3.6). In the three small trials of persistent AF patients, procedural cardiac tamponade occurred in 4 to 9.5 percent of patients, with a pooled estimate of 5.4 percent (95% CI 2.1 to 13.7).

###### Pericardial Effusion

Five RCTs (one good and four fair quality) reported an overall risk of pericardial effusion (not leading to tamponade) following RFA that ranged from 0.5 to 0.9 percent (Figure 10, Table 26). 35, 41, 45, 47, 83 These trials enrolled between 116 and 194 patients each. Across the three RCTs of paroxysmal AF patients, pericardial effusion occurred in 0.5 to 0.7 percent of RFA patients (range, 139–194 patients per study), with a pooled estimate of 0.6 percent (95% CI 0.2 to 1.8).35, 42, 47, 83 One RCT reported pericardial effusion in 0.9 percent of 116 persistent AF patients,41 and another RCT reported a similar risk in a mixed AF population of patients (0.7% of 139 patients).47

One fair-quality prospective observational study reported pericardial effusion in 1.9 percent (3/158) elderly patients (mean age 75 years, Medicare population) with persistent AF who received RFA (Table 27).48

Across four case series, pericardial effusion was reported in 0.1 to 6.0 percent of RFA patients (N=1011–59470).55, 58, 64, 67 Three case series reported cardiac tamponade or pericardial effusion requiring pericardiocentesis occurred in0.4 percent of 5947 RFA patients,67 0.8 percent of 1506 RFA procedures,71 and 1.7 percent of 15,423 patients who underwent ablation using a variety of energy sources (Appendix H, Table H4).65

Figure 10 Risk of pericardial effusion following RFA from RCTs in patients with paroxysmal AF

AF = atrial fibrillation; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation.

Figure 10. This figure is a bar graph that displays the percentage of patients who had pericardial effusion (not leading to tamponade) following radiofrequency ablation (RFA) as reported by five randomized controlled trials (RCTs). All RCTs were in patients with paroxysmal atrial fibrillation and followup periods ranged from 1 to 48 months. The risk of pericardial effusion ranged from 0.5 to 0.7 percent with a pooled percent of 0.6 (95% confidence interval 0.2 to 1.8).

###### Pulmonary Vein Stenosis

Pulmonary vein stenosis was reported in 0 to 3.1 percent of patients following RFA by eight RCTs, of which one was good quality and seven were fair quality (Figure 11, Table 26).35, 38, 40–42, 45–47 In the five trials of paroxysmal AF patients, pulmonary vein stenosis occurred in 0 to 3.1 percent of patients, with 32 to 194 RFA patients per study.35, 38, 42, 46, 47 Of the two trials with 12 months followup, the pooled estimate indicated that pulmonary vein stenosis occurred in 1.6 percent (95% CI 0.4 to 6.3) of patients.38, 46 For the two trials with 24 months followup, the pooled estimate was 0.7 percent (95% CI 0.2 to 2.8).35, 42 Two RCTs of persistent AF patients (N=21–116) reported pulmonary vein stenosis in 0 to 0.9 percent following RFA, with a pooled estimate of 0.7 percent (95% CI 0.1 to 5.0).40, 41 One study of a mixed population of paroxysmal and persistent AF patients reported no cases of this complication in 137 RFA patients.45

Three comparative observational studies reported pulmonary vein stenosis in 0 to 7.1 percent of patients, with 85 to 158 RFA patients per study (Table 27).48, 51, 52 Two of these studies were fair quality48, 52 and one was poor quality.51 Of note, study of 158 Medicare population patients (mean age, 75 years) with persistent AF reported no cases of pulmonary vein stenosis.48

Across seven case series, pulmonary vein stenosis was reported in: 0 to 1.4 percent of RFA patients (N=1000–1380),55, 57, 58, 64 0.08 to 0.4 percent of 1190 to 1506 RFA procedures,59, 71 and 0.2 percent of patients who underwent procedures using a variety of energy sources (N=1273) (Appendix H, Table H4).60

Figure 11 Risk of pulmonary vein stenosis following RFA from RCTs in patients with paroxysmal or persistent AF

AF = atrial fibrillation; RCT = randomized controlled trial; RFA = radiofrequency catheter ablation.

*Patients with heart failure.

Figure 11. This figure is a bar graph that displays the percentage of paroxysmal and persistent AF patients who had pulmonary vein (PV) stenosis following radiofrequency ablation (RFA) as reported by six randomized controlled trials (RCTs) with follow-up of six months or greater. Four trials were in paroxysmal AF patients and the overall risk of PV stenosis ranged from 0.5 to 3.1 percent of patients. The pooled risk of PV stenosis was 1.6 percent (95% confidence interval [CI] 0.4 to 6.3) in the two trials with 12 months followup and 0.7 percent (95% CI 0.2 to 2.8) in the two trials with 24 months followup. Two RCTs of persistent AF patients reported PV stenosis in 0 to 0.9 percent following RFA, with a pooled estimate of 0.7 percent (95% CI 0.1 to 5.0).

###### Other Ablation-Related Complications

Atrioesphoageal fistula occurred in no RFA patients as reported from two fair-quality RCTs of 89 to 139 paroxysmal AF patients42, 47 as well as from one study of 158 elderly Medicare population patients with persistent AF (Table 26).48 Across five case series, atrioesophageal fistula was reported in: 0 to 0.2 percent of RFA patients (N=1000–1380)57, 58, 64 and in 0 to 0.07 percent of 1190 to 1506 RFA procedures (Appendix H, Table H4).59, 71

Other ablation-related harms reported in the RCTs included chest infection (1 RCT, 3.8%),39 phrenic nerve paralysis (1 RCT, 0.7%),45 perforation at the trans-septal puncture (1 RCT, 0.5%),35 and perimyocarditis (3 RCTs, 0% to 1.7%).35, 41, 47 There were no instances of diaphragmatic paralysis, heart block, or pneumothorax as reported by one RCT of 139 patients (Table 26).47

One poor-quality comparative observational study reported iatrogenic left atrial flutter/tachycardia in 8.2 percent (7/85) of ablation patients treated for paroxysmal, persistent or permanent AF over a mean followup period of 15 months (timing not reported) (Table 27).51

Two case series reported that hematoma occurred in 2.1 to 3.7 percent of patients who underwent ablation using a variety of energy sources (N=1273–6207) (Appendix H, Table H4).60, 70

Across the case series, other ablation harms were reported to occur in 0 to 0.7 percent of patients or procedures, including: pericardial complications,62 arteriovenous fistula,55, 57, 59, 71 atrioventricular fistula,56 persistent postoperative fistula,67 phrenic nerve paralysis,55, 58, 59, 63, 64, 67 phrenic nerve injury,71 heart block,55, 59, 87 perforation at trans-septal puncture,55 esophageal perforation,56 endocarditis,57 pneumothorax,55, 61, 62, 67 hemothorax,59, 61, 55 mitral valve injury,59 or iatrogenic respiratory complications (Appendix H, Table H4).62 One case series reported iatrogenic cardiac complications in 1.2 percent of 93,801 RFA procedures.62

###### Drug Therapy-Related Adverse Events

###### Drug Intolerance Leading To Discontinuation

Three RCTs reported drug intolerance (Table 26).36, 44, 47 Two fair-quality small RCTs of paroxysmal AF patients reported disabling or serious drug intolerance requiring discontinuation of therapy in 5.4 to 23.2 percent of medical therapy patients.44, 47 Wilber et al. did not describe the symptoms that led to the withdrawal,47 but Pappone et al. listed reasons for discontinuation as pro-arrhythmia, thyroid dysfunction, and sexual impairment.44 One fair-quality RCT of a mixed AF population indicated one (2.9%) RFA patient developed bradycardia post-ablation and discontinued medical therapy; no cases were reported for the medical therapy group.45

One fair-quality prospective comparative observational study of 412 persistent AF patients with a mean age of 75 (i.e., Medicare population) reported discontinuation of antiarrhythmic therapy due to intolerance or side effects in significantly fewer RFA (2.6%) versus medical therapy patients (12.7%) (p=0.0005) (Table 27).48 The primary reasons for discontinuation included worsening sick sinus syndrome (1.3% vs. 5.8%, respectively; p=0.037) and dysthyroidism (0.7% vs. 5.4%, respectively; p=0.013).

###### Toxicity

Two RCTs described drug-related toxicity (Table 26). Thyrotoxicosis, which was defined as transient and subclinical suppressed thyroid levels, developed in 0 percent RFA patients versus 19.2 percent medical therapy patients in one fair-quality trial of 198 paroxysmal patients.83 Another fair-quality RCT of paroxysmal patients reported hyperthyroidism in 1.7 percent of 59 medical therapy patients.38 Other reports of drug-related toxicity were confined to one fair-quality RCT of paroxysmal AF patients, and included hepatoxicity (1.0%), dermatological toxicity (2.0%), and ophthalmological toxicity (2.0%) in the medical therapy group (with no cases in the RFA group).83

###### Sexual Impairment

One fair-quality RCT of 198 paroxysmal AF patients reported sexual impairment in 0 percent of RFA and 11.1 percent of medical therapy patients (Table 26).83

###### Other Drug Therapy-Related Adverse Events

Other drug therapy-related adverse events included atrial flutter attributed to flecainide (1 RCT),36 symptomatic bradycardia attributed to medical therapy (within 12 months followup) (1 RCT),36 symptomatic sinus node dysfunction requiring pacemaker implantation (1 RCT),36 weakness/tiredness (1 RCT),35 flecainide intoxication (1 RCT),41 hematoma related to anticoagulation (2 RCTs),35, 41 and occurred in less than 2 percent of patients (Table 26).

###### Peripheral Vascular Complications

Hematomas developed at the catheter insertion site in 1.6 to 3.8 percent of RFA patients as reported by four RCTs (range, 26–186 patients per study) (Table 26).36, 38, 39, 83 None of the comparative observational studies reported this complication.

Two RCTs reported vascular injury due to access occurred in 0.7 percent patients to 3.4 percent procedures (range, 116 patients to 139 procedures) (Table 26),41, 47 while one prospective observational study of 412 persistent AF patients with a mean age of 75 (i.e., Medicare population) reported this complication in 0.7 percent of 153 RFA patients (Table 27).48

Across the case series, peripheral vascular complications were reported to occur in 0.1 to 2.6 percent of patients or procedures, including: hematoma at catheter insertion site,58 vascular injury due to access,60, 64 vascular complications requiring surgical repair,61, 62, 65 retroperitoneal hematoma,57 and pseudoaneurysm (Appendix H, Table H4).55, 57, 59

###### Other Adverse Events

Adverse events not attributable to either treatment were reported following RFA versus medical therapy, and included deep vein thrombosis (0% vs. 0%, 2 RCTs),36, 46 pulmonary embolism (0% vs. 0%, 2 RCTs),36, 46 and pneumonia (1.0% vs. 0%, 1 RCT).47 Pulmonary edema risk was similar in the RFA versus medical therapy treatment groups as reported by four RCTs (0%–3.8% vs. 0%–4.0% of patients) (52 to 198 patients per trial) (Table 26).36, 39, 47, 83

One prospective cohort study of elderly (mean age 75 years, Medicare population) persistent AF patients reported no cases of minor bleeding (Table 27).48 Another retrospective comparative observational study of a Medicare-relevant patient population (mean age, 67 years) reported several events that led to death during the 69 ± 27 month followup: respiratory failure (0% vs. 1.5%), infection (0% vs. 1.0%), and cancer (0% vs. 1.5%).53 Finally, one administrative database study of the MarketScan database reported no difference in three-year pneumonia-related hospitalization rate estimates between ablation and no ablation groups (2.6% versus 2.4%).50 Otherwise, no other adverse events were reported in the comparative observational studies.

One administrative database study reported that 9.4 percent of patients required rehospitalization for any cause (N=4156).61 One case series reported pulmonary hypertension in 1.4 percent of 1380 RFA patients.58 Otherwise, across the case series, other harms were reported to occur in 0.08 to 0.8 percent of patients or procedures, including: postoperative infections,62 deep vein thrombosis,57, 64 respiratory compromise or failure,59, 62 aspiration with or without pneumonia,57 and the need for open heart surgery (Appendix H, Table H4).62

Table 26 Adverse events for RCTs comparing RFA with medical therapy

Adverse Event | | AF Type (1st/2nd line therapy) | Study | Followup | RFA % (n/N) | Medical Therapy % (n/N)
Major Events | Mortality (cardiovascular) <30 days | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | Periprocedural | 0.7% (1/140)^*^ | 0% (0/146)
Major Events | Mortality (cardiovascular) <30 days | Paroxysmal (1st line) | Morillo 2014^42^ | 1 month | 0% (0/65) | 0% (0/60)
Major Events | Mortality (cardiovascular) <30 days | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/103) | 0% (0/56)
Major Events | Mortality (cardiovascular) <30 days | Persistent (2nd line) | Mont 2013^41^ | 1 month | 0% (0/93) | 0% (0/48)
Major Events | Mortality (cardiovascular) <30 days | Persistent (1st/2nd line) | Hunter 2014^37^ | Periprocedural | 0% (0/26) | 4.2% (1/24)
Major Events | Mortality (all cause) <30 days | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | Periprocedural | 0.7% (1/140)^*^ | 0% (0/146)
Major Events | Mortality (all cause) <30 days | Paroxysmal (1st line) | Morillo 2014^42^ | 1 month | 0% (0/65) | 0% (0/60)
Major Events | Mortality (all cause) <30 days | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/103) | 0% (0/56)
Major Events | Mortality (all cause) <30 days | Persistent (2nd line) | Mont 2013^41^ | 1 month | 0% (0/93) | 0% (0/48)
Major Events | Mortality (all cause) <30 days | Persistent (1st/2nd line) | Hunter 2014^37^ | Periprocedural | 0% (0/26) | 4.2% (1/24)
Major Events | Stroke (any type) <30 days | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | Periprocedural | 0.7% (1/140)^*^ | 0% (0/146)
Major Events | Stroke (any type) <30 days | Paroxysmal (1st line) | Morillo 2014^42^ | 1 month | 0% (0/65) | 0% (0/60)
Major Events | Stroke (any type) <30 days | Paroxysmal (1st line) | Wazni 2005^46^ | 1 month | 0% (0/33) | 0% (0/37)
Major Events | Stroke (any type) <30 days | Persistent (2nd line) | MacDonald 2011^40^ | Periprocedural | 4.8% (1/21) | 0% (0/19)
Major Events | Stroke (any type) <30 days | Persistent (2nd line) | Mont 2013^41^ | 1 month | 0% (0/93) | 0% (0/48)
Major Events | Stroke (any type) <30 days | Persistent (1st/2nd line) | Hunter 2014^37^ | Periprocedural | 3.8% (1/26) | 0% (0/24)
Major Events | Stroke (any type) <30 days | Mixed (2nd line) | Forleo 2009^36^ | 1 month | 0% (0/35) | 0% (0/35)
Major Events | Stroke (any type) <30 days | Mixed (2nd line) | Stabile 2006^45^ | Periprocedural | 1.5% (1/68)^†^ | 0% (0/69)
Major Events | Myocardial infarction <30 days | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/103) | 0% (0/56)
Major Events | Transient ischemic attack <30 days | Paroxysmal (1st line) | Morillo 2014^42^ | 1 month | 0% (0/65) | 0% (0/60)
Major Events | Transient ischemic attack <30 days | Paroxysmal (1st line) | Wazni 2005^46^ | 1 month | 0% (0/33) | 0% (0/37)
Major Events | Transient ischemic attack <30 days | Paroxysmal (2nd line) | Pappone 2006 | Periprocedural | 1.0% (1/99) | 0% (0/99)
Major Events | Transient ischemic attack <30 days | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/103) | 0% (0/56)
Major Events | Transient ischemic attack <30 days | Persistent (2nd line) | Mont 2013^41^ | 1 month | 0% (0/93) | 0% (0/48)
Major Events | Transient ischemic attack <30 days | Mixed (2nd line) | Forleo 2009^36^ | 1 month | 0% (0/35) | 0% (0/35)
Major Events | Other embolic events <30 days | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/103) | 0% (0/56)
Major Events | Bleeding (major)/ hemorrhage/ transfusion (<30 days) | Paroxysmal (1st line) | Wazni 2005^46^ | 1 month | 6.3% (2/32) | 1.9% (1/35)
Major Events | Bleeding (major)/ hemorrhage/ transfusion (<30 days) | Mixed (2nd line) | Forleo 2009^36^ | 1 month | 5.7% (2/35)^‡^ | 5.7% (2/35)^‡^
Major Events | Heart failure <30 days | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 1.0% (1/103) | 0% (0/56)
Major Events | Heart failure <30 days | Persistent (2nd line) | MacDonald 2011^40^ | Periprocedural | 14.3% (3/21) | 0% (0/19)
Major Events | “Major complications” (overall) | Persistent (2nd line) | MacDonald 2011^40^ | Periprocedural | 14.8% (4/27 procedures)^§^ | NR
Arrhythmia (<3 months)^**^ | Atrial fibrillation | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | 3 months | 30.7% (43/140) | 37.7% (55/146)
Arrhythmia (<3 months)^**^ | Atrial fibrillation | Paroxysmal (1st line) | Wazni 2005^46^ | 2 months | 27.3% (9/33) | 54.1% (20/37)
Arrhythmia (<3 months)^**^ | Atrial fibrillation | Paroxysmal (2nd line) | Pappone 2006^44^ | 1.5 months | 11.1% (11/99) | NR
Arrhythmia (<3 months)^**^ | Atrial fibrillation | Persistent (2nd line) | MacDonald 2011^40^ | 3 months | 47.6% (10/21) | NR
Arrhythmia (<3 months)^**^ | Atrial fibrillation | Persistent (2nd line) | Oral 2006^43^ | 2 months | 18.2% (14/77) | 97.1% (67/69)
Arrhythmia (<3 months)^**^ | Atrial fibrillation | Persistent (1st/2nd line) | Hunter 2014^37^ | 3 months | 15.4% (4/26) | 100% (24/24)
Arrhythmia (<3 months)^**^ | Atrial flutter | Paroxysmal (1st line) | Morillo 2014^42^ | NR (F/U to 24 mos.) | 0% (0/65) | 1.5% (1/60)^††^
Arrhythmia (<3 months)^**^ | Atrial flutter | Paroxysmal (2nd line) | Pappone 2006^44^ | NR (F/U to 12 mos.) | 0% (0/99) | 0.1% (1/99)^††^
Arrhythmia (<3 months)^**^ | Atrial flutter | Persistent (2nd line) | Oral 2006^43^ | 2 months | 5.2% (4/77) | 0% (0/69)
Arrhythmia (<3 months)^**^ | Atrial fibrillation or atrial flutter | Persistent (2nd line) | Mont 2013^41^ | 3 months | 29.6% (NR/93) | 54.2% (NR/48)
Arrhythmia (<3 months)^**^ | Atrial fibrillation or atrial flutter | Mixed (2nd line) | Forleo 2009^36^ | 5 weeks | 8.6% (3/35) | 14.3% (5/35)
Arrhythmia (<3 months)^**^ | Arrhythmia (type NR) | Paroxysmal (1st line) | Morillo 2014^42^ | 3 months | 1.5% (1/65) | 5.0% (3/60)
Arrhythmia (<3 months)^**^ | Arrhythmia (type NR) | Paroxysmal (2nd line) | Pappone 2011^83^ | NR (F/U to 48 mos.) | 0% (0/99) | 10.1% (10/99)^††^
Arrhythmia (<3 months)^**^ | Arrhythmia (type NR) | Persistent (1st/2nd line) | Jones 2013^39^ | 2 months | 30.8% (8/26) | NR
Arrhythmia (<3 months)^**^ | Arrhythmia (type NR) | Mixed (2nd line) | Forleo 2009^36^ | Periprocedural | 5.7% (2/35)^‡‡^ | NA
Arrhythmia (<3 months)^**^ | Arrhythmia (type NR) | Mixed (2nd line) | Stabile 2006^45^ | 1 month (blanking) | 35.3% (24/68) | 71.0% (49/69)
Arrhythmia (<3 months)^**^ | Bradycardia | Paroxysmal (1st line) | Morillo 2014^42^ | NR (F/U to 24 mos.) | 1.5% (1/65)^††^ | 0% (0/60)
Arrhythmia (<3 months)^**^ | Bradycardia | Paroxysmal (2nd line) | Pappone 2011^83^ | NR (F/U to 48 mos.) | 0% (0/99) | 15.2% (15/99)
Arrhythmia (<3 months)^**^ | Hospitalization for direct current cardioversion and medication adjustment | Paroxysmal (1st line) | Wazni 2005^46^ | 2 months | 0% (0/33) | 54.1% (20/37)
Arrhythmia (<3 months)^**^ | Tachycardia | Paroxysmal (2nd line) | Pappone 2006^44^ | 72–102 days | 9.1% (9/99) | 36.4% (36/99)
Arrhythmia (<3 months)^**^ | Ventricular arrhythmia | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/103) | 0% (0/56)
Ablation-Related Events^§§^ | Cardiac tamponade | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | NR (F/U to 24 mos.) | 1.5% (3/194) | NA
Ablation-Related Events^§§^ | Cardiac tamponade | Paroxysmal (1st line) | Morillo 2014^42^ | NR (F/U to 24 mos.) | 4.5% (4/89) | NA
Ablation-Related Events^§§^ | Cardiac tamponade | Paroxysmal (2nd line) | Jais 2008^38^ | NR (F/U to 12 mos.) | 2.2% (2/90) | NA
Ablation-Related Events^§§^ | Cardiac tamponade | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/139) | NA
Ablation-Related Events^§§^ | Cardiac tamponade | Persistent (2nd line) | MacDonald 2011^40^ | Periprocedural | 9.5% (2/21) | NA
Ablation-Related Events^§§^ | Cardiac tamponade | Persistent (1st/2nd line) | Hunter 2014^37^ | Periprocedural | 3.8% (1/26) | NA
Ablation-Related Events^§§^ | Cardiac tamponade | Persistent (1st/2nd line) | Jones 2013^39^ | Periprocedural | 3.8% (1/26) | NA
Ablation-Related Events^§§^ | Pericardial effusion | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | NR (F/U to 24 mos.) | 0.5% (1/194) | NA
Ablation-Related Events^§§^ | Pericardial effusion | Paroxysmal (2nd line) | Pappone 2011^83^ | Periprocedural | 0.5% (1/186) | NA
Ablation-Related Events^§§^ | Pericardial effusion | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0.7% (1/139) | NA
Ablation-Related Events^§§^ | Pericardial effusion | Persistent (2nd line) | Mont 2013^41^ | Periprocedural | 0.9% (1/116) | NA
Ablation-Related Events^§§^ | Pericardial effusion | Mixed (2nd line) | Stabile 2006^45^ | Periprocedural | 0.7% (1/137) | NA
Ablation-Related Events^§§^ | Pulmonary vein stenosis | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | NR (F/U to 24 mos.) | 0.5% (1/194) | NA
Ablation-Related Events^§§^ | Pulmonary vein stenosis | Paroxysmal (1st line) | Morillo 2014^42^ | NR (F/U to 24 mos.) | 1.1% (1/89) | NA
Ablation-Related Events^§§^ | Pulmonary vein stenosis | Paroxysmal (1st line) | Wazni 2005^46^ | NR (F/U to 12 mos.) | 3.1% (1/32) | NA
Ablation-Related Events^§§^ | Pulmonary vein stenosis | Paroxysmal (2nd line) | Jais 2008^38^ | NR (F/U to 12 mos.) | 1.1% (1/90) | NA
Ablation-Related Events^§§^ | Pulmonary vein stenosis | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/139) | NA
Ablation-Related Events^§§^ | Pulmonary vein stenosis | Persistent (2nd line) | MacDonald 2011^40^ | NR (F/U to 6 mos.) | 0% (0/21) | NA
Ablation-Related Events^§§^ | Pulmonary vein stenosis | Persistent (2nd line) | Mont 2013^41^ | NR (F/U to 12 mos.) | 0.9% (1/116) | NA
Ablation-Related Events^§§^ | Pulmonary vein stenosis | Mixed (2nd line) | Stabile 2006^45^ | NR (F/U to 12 mos.)^***^ | 0% (0/137) | NA
Ablation-Related Events^§§^ | Atrioesophageal fistula | Paroxysmal (1st line) | Morillo 2014^42^ | NR (F/U to 24 mos.) | 0% (0/89) | NA
Ablation-Related Events^§§^ | Atrioesophageal fistula | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/139) | NA
Ablation-Related Events^§§^ | Chest infection | Persistent (1st/2nd line) | Jones 2013^39^ | 2 weeks | 3.8% (1/26) | NA
Ablation-Related Events^§§^ | Phrenic nerve paralysis | Mixed (2nd line) | Stabile 2006^45^ | Periprocedural | 0.7% (1/137) | NA
Ablation-Related Events^§§^ | Perforation at transseptal puncture | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | NR (F/U to 24 mos.) | 0.5% (1/194) | NA
Ablation-Related Events^§§^ | Perimyocarditis | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | NR (F/U to 24 mos.) | 0.5% (1/194) | NA
Ablation-Related Events^§§^ | Perimyocarditis | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/139) | NA
Ablation-Related Events^§§^ | Perimyocarditis | Persistent (2nd line) | Mont 2013^41^ | Periprocedural | 1.7% (2/116) | NA
Ablation-Related Events^§§^ | Diaphragmatic paralysis | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/139) | NA
Ablation-Related Events^§§^ | Heart block | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/139) | NA
Ablation-Related Events^§§^ | Pneumothorax | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/139) | NA
Drug Therapy-Related Adverse Events^**^ | Drug intolerance requiring discontinuation | Paroxysmal (2nd line) | Pappone 2006^44^ | NR (F/U to 12 mos.) | 0% (0/99) | 23.2% (23/99)
Drug Therapy-Related Adverse Events^**^ | Drug intolerance requiring discontinuation | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0% (0/103) | 5.4% (3/56)
Drug Therapy-Related Adverse Events^**^ | Drug intolerance requiring discontinuation | Mixed (2nd line) | Forleo 2009^36^ | NR (F/U to 12 mos.) | 2.9% (1/35) | 0% (0/35)
Drug Therapy-Related Adverse Events^**^ | Thyrotoxicosis (transient, subclinical) | Paroxysmal (2nd line) | Pappone 2011^83^ | NR (F/U to 48 mos.) | 0% (0/99) | 19.2% (19/99)
Drug Therapy-Related Adverse Events^**^ | Hyperthyroidism | Paroxysmal (2nd line) | Jais 2008^38^ | NR (F/U to 12 mos.) | NA | 1.7% (1/59)
Drug Therapy-Related Adverse Events^**^ | Toxicity (hepatotoxicity) | Paroxysmal (2nd line) | Pappone 2011^83^ | NR (F/U to 48 mos.) | 0% (0/99) | 1.0% (1/99)
Drug Therapy-Related Adverse Events^**^ | Toxicity (dermatological toxicity) | Paroxysmal (2nd line) | Pappone 2011^83^ | NR (F/U to 48 mos.) | 0% (0/99) | 2.0% (2/99)
Drug Therapy-Related Adverse Events^**^ | Toxicity (ophthalmological toxicity) | Paroxysmal (2nd line) | Pappone 2011^83^ | NR (F/U to 48 mos.) | 0% (0/99) | 2.0% (2/99)
Drug Therapy-Related Adverse Events^**^ | Sexual impairment (severe) | Paroxysmal (2nd line) | Pappone 2011^83^ | NR (F/U to 48 mos.) | 0% (0/99) | 11.1% (11/99)
Drug Therapy-Related Adverse Events^**^ | Weakness/tiredness (attributed to drug therapy) | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | NR (F/U to 24 mos.) | 0% (0/140) | 1.4% (2/146)
Drug Therapy-Related Adverse Events^**^ | Hematoma related to anticoagulation | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | NR (F/U to 24 mos.) | 0.7% (1/140) | 0% (0/146)
Drug Therapy-Related Adverse Events^**^ | Hematoma related to anticoagulation | Persistent (2nd line) | Mont 2013^41^ | NR (F/U to 12 mos.) | 1.7% (1/93) | 0% (0/48)
Drug Therapy-Related Adverse Events^**^ | Atrial flutter attributed to flecainide | Mixed (2nd line) | Forleo 2009^36^ | NR (F/U to 12 mos.) | 2.9% (1/35) | NR
Drug Therapy-Related Adverse Events^**^ | Symptomatic bradycardia attributed to medical therapy | Mixed (2nd line) | Forleo 2009^36^ | NR (F/U to 12 mos.) | NR | 14.3% (5/35)
Drug Therapy-Related Adverse Events^**^ | Symptomatic sinus node dysfunction attributed to medical therapy | Mixed (2nd line) | Forleo 2009^36^ | NR (F/U to 12 mos.) | NR | 2.9% (1/35)^†††^
Drug Therapy-Related Adverse Events^**^ | Flecainide intoxication | Persistent (2nd line) | Mont 2013^41^ | NR (F/U to 12 mos.) | 0% (0/93) | 2.1% (1/48)
Peripheral Vascular Complications | Hematoma at catheter insertion site | Paroxysmal (2nd line) | Jais 2008^38^ | NR (F/U to 12 mos.) | 2.2% (2/90) | NA
Peripheral Vascular Complications | Hematoma at catheter insertion site | Paroxysmal (2nd line) | Pappone 2011^83^ | Periprocedural | 1.6% (3/186) | NA
Peripheral Vascular Complications | Hematoma at catheter insertion site | Persistent (1st/2nd line) | Jones 2013^39^ | Periprocedural | 3.8% (1/26) | NA
Peripheral Vascular Complications | Hematoma at catheter insertion site | Mixed (2nd line) | Forleo 2009^36^ | Periprocedural | 2.9% (1/35) | NA
Peripheral Vascular Complications | Vascular injury due to access | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 0.7% (1/139) | NA
Peripheral Vascular Complications | Vascular injury due to access | Persistent (2nd line) | Mont 2013^41^ | Periprocedural | 3.4% (4/116 procedures) | NA
Adverse Events (not ablation dependent)^‡‡‡^ | Deep vein thrombosis | Paroxysmal (1st line) | Wazni 2005^46^ | 2 months | 0% (0/33) | 0% (0/37)
Adverse Events (not ablation dependent)^‡‡‡^ | Deep vein thrombosis | Mixed (2nd line) | Forleo 2009^36^ | NR (F/U to 12 mos.) | 0% (0/35) | 0% (0/35)
Adverse Events (not ablation dependent)^‡‡‡^ | Pulmonary embolism | Paroxysmal (1st line) | Wazni 2005^46^ | 2 months | 0% (0/33) | 0% (0/37)
Adverse Events (not ablation dependent)^‡‡‡^ | Pulmonary embolism | Mixed (2nd line) | Forleo 2009^36^ | NR (F/U to 12 mos.) | 0% (0/35) | 0% (0/35)
Adverse Events (not ablation dependent)^‡‡‡^ | Pneumonia (<30 days) | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 1.0% (1/103) | 0% (0/56)
Adverse Events (not ablation dependent)^‡‡‡^ | Pulmonary edema | Paroxysmal (2nd line) | Pappone 2011^83^ | NR (F/U to 48 mos.) | 0% (0/99) | 4.0% (4/99)
Adverse Events (not ablation dependent)^‡‡‡^ | Pulmonary edema | Paroxysmal (2nd line) | Wilber 2010^47^ | 1 month | 1.0% (1/103) | 0% (0/56)
Adverse Events (not ablation dependent)^‡‡‡^ | Pulmonary edema | Persistent (1st/2nd line) | Jones 2013^39^ | Periprocedural | 3.8% (1/26) | 0% (0/26)
Adverse Events (not ablation dependent)^‡‡‡^ | Pulmonary edema | Mixed (2nd line) | Forleo 2009^36^ | NR (F/U to 12 mos.) | 0% (0/35) | 2.9% (1/35)
Adverse Events (not ablation dependent)^‡‡‡^ | Bleeding (severity NR) | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | NR (F/U to 24 mos.) | 0.7% (1/140) | 0% (0/146)
Adverse Events (not ablation dependent)^‡‡‡^ | Chest discomfort | Paroxysmal (1st line) | Cosedis Nielsen 2012^35^ | NR (F/U to 24 mos.) | 0.7% (1/140) | 0% (0/146)
Adverse Events (not ablation dependent)^‡‡‡^ | Syncope (fainting) | Paroxysmal (1st line) | Morillo 2014^42^ | NR (F/U to 24 mos.) | 0% (0/65) | 3.3% (2/60)

AF = atrial fibrillation; F/U = followup; NA = not applicable; NR = not reported; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation.

* Procedure-related cerebral stroke resulting in death. Any mortality due to cardiovascular causes is also included under all-cause mortality.

† During left atrium ablation. Patient died at 9 months.

‡ RFA: 1 subarachnoid hemorrhage and 1 intestinal bleeding accompanying an elevated INR; Medical therapy: gastrointestinal or subdural bleeding.

§ Include cerebrovascular accident, cardiac tamponade or readmission to hospital within 1 week; unclear if these are the same complications as above.

** Analysis based on patients “as treated”.

†† Drug therapy induced.

‡‡ Spontaneous atrial arrhythmias; unclear if these patient overlap with those reported under atrial fibrillation or atrial flutter, but unlikely given the timing and the language used.

§§ Denominator is the number of patients who underwent the procedure, and may include patients randomized to medical therapy that crossed over and underwent ablation.

*** Followup time included a 1-month blanking period, for a total of 13 months followup.

††† Required pacemaker insertion.

‡‡‡ Adverse events that could occur regardless of whether ablation was performed.

Table 27 Adverse events from comparative observational studies comparing RFA with medical therapy

Adverse Event | | AF Type | Study^*^ | Followup | RFA % (n/N) | Medical Therapy % (n/N)
Major Events | Mortality (all cause) <30 days | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 0% (0/153) | 0.4% (1/259)
Major Events | Stroke (any type) <30 days | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 2.6% (4/153) | 0.4% (1/259)
Major Events | Stroke (any type) <30 days | Mixed (1st/2nd line) | Rossillo 2008^51^ | Periprocedural | 1.2% (1/85) | 1.2% (1/85)
Major Events | Transient ischemic attack <30 days | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 1.3% (2/153) | 0.4% (1/259)
Major Events | Other embolic events <30 days | Paroxysmal (2nd line) | Sang 2013^52^ | ≤30 days | 0% (0/82) | 3.6% (3/84)
Major Events | Other embolic events <30 days | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 0% (0/153) | 0% (0/259)
Major Events | Myocardial infarction <30 days | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 1.3% (2/153) | 0% (0/259)
Major Events | Bleeding (major)/ hemorrhage/ transfusion (>30 days) | Persistent (2nd line) | Blandino 2013^48^ | >30 days | 1.3% (2/153) | 0.8% (2/259)
Major Events | Heart failure <30 days | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 0% (0/153) | 0% (0/259)
Major Events | “Major complications” (overall) | Paroxysmal (2nd line) | Lan 2009^49^ | NR (F/U to 12 mos.) | 5.8% (7/120)^†^ | 9.2% (11/120)^†^
Arrhythmia (<3 Months)^‡^ | Atrial fibrillation | Mixed (1st/2nd line) | Rossillo 2008^51^ | 2 months | 45.9% (39/85) | NR
Arrhythmia (<3 Months)^‡^ | Torsade de points (<3 months) | Paroxysmal (2nd line) | Lan 2009^49^ | NR (F/U to 12 mos.) | 0% (0/120) | 0% (0/120)
Ablation-Related Events^§^ | Cardiac tamponade | Paroxysmal (2nd line) | Sang 2013^52^ | 12 months | 0% (0/85) | NA
Ablation-Related Events^§^ | Cardiac tamponade | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 0% (0/158) | NA
Ablation-Related Events^§^ | Pericardial effusion | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 1.9% (3/158) | NA
Ablation-Related Events^§^ | Pulmonary vein stenosis | Paroxysmal (2nd line) | Sang 2013^52^ | 12 months | 0% (0/85) | NA
Ablation-Related Events^§^ | Pulmonary vein stenosis | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 0% (0/158) | NA
Ablation-Related Events^§^ | Pulmonary vein stenosis | Mixed (1st/2nd line) | Rossillo 2008^51^ | NR (F/U mean 15 ± 7 mos.) | 7.1% (6/85) | NA
Ablation-Related Events^§^ | Atrioesophageal fistula | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 0% (0/158) | NA
Ablation-Related Events^§^ | Iatrogenic left atrial flutter/tachycardia | Mixed (1st/2nd line) | Rossillo 2008^51^ | NR (F/U mean 15 ± 7 mos.) | 8.2% (7/85) | NA
Drug Therapy-Related Adverse Events^‡^ | AAD adverse events (leading to discontinuation) | Persistent (2nd line) | Blandino 2013^48^ | >30 days | 2.6% (4/153) | 12.7% (33/259)
Drug Therapy-Related Adverse Events^‡^ | Dysthyroidism^**^ | Persistent (2nd line) | Blandino 2013^48^ | >30 days | 0.7% (1/153) | 5.4% (14/259)
Drug Therapy-Related Adverse Events^‡^ | Arrhythmia (attributed to AADs)^**^ | Persistent (2nd line) | Blandino 2013^48^ | >30 days | 1.3% (2/153)^††^ | 5.8% (15/259)^††^
Peripheral Vascular Complications | Vascular injury due to access | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 0.7% (1/153) | 0% (0/259)
Adverse Events (not ablation dependent)^§§^ | Minor bleeding | Persistent (2nd line) | Blandino 2013^48^ | ≤30 days | 0% (0/153) | 0% (0/259)
Adverse Events (not ablation dependent)^§§^ | Respiratory failure^‡‡^ | Mixed (2nd line) | Sonne 2009^53^ | NR (F/U mean 69 ± 27 mos.) | 0% (0/146) | 1.5% (3/205)
Adverse Events (not ablation dependent)^§§^ | Infection (not otherwise specified) ‡‡ | Mixed (2nd line) | Sonne 2009^53^ | NR (F/U mean 69 ± 27 mos.) | 0% (0/146) | 1.0% (2/205)
Adverse Events (not ablation dependent)^§§^ | Cancer^‡‡^ | Mixed (2nd line) | Sonne 2009^53^ | NR (F/U mean 69 ± 27 mos.) | 0% (0/146) | 1.5% (3/205)
Adverse Events (not ablation dependent)^§§^ | Other unspecified complications^‡‡^ | Mixed (2nd line) | Sonne 2009^53^ | NR (F/U mean 69 ± 27 mos.) | 0% (0/146) | 1.5% (3/205)
Adverse Events (not ablation dependent)^§§^ | Pneumonia hospitalization | NR | Reynolds 2012^50^ | Mean 27 months | Annualized rate^***^: 1.0% Kaplan-Meier estimate^†††^: 2.6% | Annualized rate^***^: 0.6% Kaplan-Meier estimate^†††^: 2.4%

AF = atrial fibrillation; F/U = followup; NA = not applicable; NR = not reported; RFA = radiofrequency catheter ablation.

* Blandino 2013 and Sonne 2009 represent the Medicare population (age ≥75 years and mean age 67 years, respectively); all other studies represent the general adult population.

† Authors do not report the number of patients with each complication which included pericardial tamponade which required pericardiocentesis, moderate to severe pulmonary vein stenosis and cerebral embolism leading to transient retrograde amnesia in the ablation group; sinus bradycardia, hypotension, significant QT prolongation, hyperthyroidism, hypothyroidism and hepatic deterioration in the drug therapy group.

‡ Analysis based on patients “as treated”.

§ Denominator is the number of patients who underwent the procedure.

** The main causes for AAD discontinuation; included in AAD adverse events above.

†† Worsening of sick sinus syndrome.

§§ Adverse events that could occur regardless of whether ablation was performed.

‡‡ All events resulted in death.

*** Annualized rate calculated as percentage (number of patients in the cohort who had an event within 3 years/average length of followup in the cohort).

††† Product-limit estimates of the 3-year event rates (percentages) and P values of the nonparametric log-rank test comparing survival functions of the 2 cohorts.

### Cryoablation Versus Medical Therapy

#### Description of Included Studies

One randomized controlled trial compared AF cryoballoon ablation with medical therapy;86 an article with additional data from the cryoablation arm only was also recently published.73 See Key Question 1a as well as the detailed demographics tables for general study characteristics (Appendix E, Tables E13–E14). The study consisted of 78 percent paroxysmal and 22 percent persistent AF patients. There was substantial crossover from medical therapy to cryoballoon ablation, with 79 percent of patients allocated to medical therapy eventually receiving cryoballoon ablation. Crossover from cryoballoon ablation to medical therapy was not reported. Adverse events attributable to either ablation or medical therapy were reported on an as-treated basis and thus data includes crossover patients.

#### Detailed Synthesis

##### Major Adverse Events

###### Mortality (cardiovascular or all-cause) (within 30 days)

No deaths were reported to occur within 30 days of treatment initiation in either treatment group (Table 28).86

###### Stroke (any type) (within 30 days)

There was no difference in the incidence of stroke within a month of treatment initiation between cryoballoon ablation and medical therapy groups (0.6% vs. 0%) (Table 28). Overall, 1.3 percent of all patients who underwent cryoballoon ablation experienced a stroke within 30 days of ablation. Of the two strokes that occurred within 30 days, one occurred in a medical therapy patient who crossed over to cryoballoon ablation and was considered procedure-related, and the other manifested as a transient bilateral visual disturbance 1 month post-ablation. Both patients recovered without any negative sequelae.86

###### Myocardial Infarction (within 30 days)

There was no difference in the incidence of myocardial infarction within a month of treatment initiation between the cryoballoon ablation and medical therapy groups (0.6% vs. 0%) (Table 28). One patient experienced a periprocedural non-Q-wave myocardial infarction that was attributed to the anesthesia.86

###### Transient Ischemic Attack (within 30 days)

TIA occurred within a month of treatment initiation in 1.8 percent of patients randomized to cryoballoon ablation and 0 percent in those allocated to medical therapy (Table 28). Overall, 1.7 percent (4/228) patients who received cryoballoon ablation, including crossover patients, experienced a TIA within 30 days of ablation.86

###### Other Embolic Events (within 30 days)

No other embolic events were reported.

###### Major Bleeding, Hemorrhage, or Transfusion (within 30 days)

There was no difference in the incidence of major bleeding complications, including subarachnoid hemorrhage (one patient), intestinal bleeding (two patients), and subdural bleeding (one patient), between the cryoballoon ablation and medical therapy groups (1.2% vs. 2.4%) (Table 28).86

###### Arrhythmia (within 3 months)

###### Atrial Fibrillation

AF recurrence within 3 months of treatment initiation was reported in 51.5% (84/163) of cryoablation patients; no data were reported for the medical therapy group.73, 86

###### Other Types of Arrhythmia (within 3 months)

Atrial flutter within 3 months was not reported.

###### Ablation-Related Adverse Events

###### Cardiac Tamponade

Cardiac tamponade occurred in 0.9 percent of all patients who received cryoballoon ablation, including crossover patients (2/228) (Table 28).86

###### Pericardial Effusion

Pericardial effusion was not reported.

###### Pulmonary Vein Stenosis

Pulmonary vein stenosis was reported in 3.1 percent of patients treated with cryoballoon ablation, including crossover patients (7/228) (Table 28).86

###### Other Ablation-Related Complications

Atrioesphoageal fistula occurred in no patients who underwent cryoballoon ablation (n=228), although one patient developed Wegener’s related hemoptysis (0.4%) (Table 24).86

Other ablation-related harms reported in the 228 patients who received cryoballoon ablation included phrenic nerve palsy (12.3%), arteriovenous fistula (0.9%), and pseudoaneurysm (0.9%) (Table 28).86

###### Drug Therapy-Related Adverse Events

No drug therapy related adverse events were reported.

###### Peripheral Vascular Complications

No peripheral vascular complications were reported.

###### Other Adverse Events

Adverse events not attributable to either treatment were reported.

Table 28 Adverse events for the RCT by Packer et al 2013 comparing cryoballoon ablation with medical therapy72

Adverse Event | | Followup | Cryoballoon Ablation^*^ % (n/N) | Medical Therapy^*^ % (n/N)
Major Events | Mortality (cardiovascular) <30 days | NR (followed to 12 months) | 0% (0/163) | 0% (0/82)
Major Events | Mortality (all-cause) <30 days | NR (followed to 12 months) | 0% (0/163) | 0% (0/82)
Major Events | Stroke (any type) <30 days | NR (followed to 12 months) | 0.6% (1/163) | 1.2% (1/82)
Major Events | Myocardial infarction <30 days | Periprocedural | 0.6% (1/163) | 0% (0/82)
Major Events | Transient ischemic attack <30 days | <20 days of ablation | 1.8% (3/163) | 0% (0/82)
Major Events | Bleeding (major)/ hemorrhage (<30 days) | NR (followed to 12 months) | 1.2% (2/163) | 2.4% (2/82)
Arrhythmia (<3 Months) | Atrial fibrillation | 3 months | 51.5% (84/163) | NR
Ablation-Related Events^†^ | Cardiac tamponade | NR (followed to 12 months) | 0.9% (2/228) | NA
Ablation-Related Events^†^ | Pulmonary vein stenosis | NR (followed to 12 months) | 3.1% (7/228) | NA
Ablation-Related Events^†^ | Atrioesophageal fistula | NR (followed to 12 months) | 0% (0/228) | NA
Ablation-Related Events^†^ | Wegener's related hemoptysis | NR (followed to 12 months) | 0.4% (1/228) | NA
Ablation-Related Events^†^ | Phrenic nerve palsy | NR (followed to 12 months) | 12.3% (28/228) | NA
Ablation-Related Events^†^ | Arteriovenous fistula | NR (followed to 12 months) | 0.9% (2/228) | NA
Ablation-Related Events^†^ | Pseudoaneurysm | NR (followed to 12 months) | 0.9% (2/228) | NA

AF = atrial fibrillation; NA = not applicable; NR = not reported; RCT = randomized controlled trial.

* Patients had paroxysmal or persistent AF (i.e. mixed) and were undergoing treatment as a 2^nd^ line therapy.

† Denominator is the number of patients who underwent the procedure.

## Key Question 2b What are the comparative short- and long-term complications and harms (e.g., periprocedural or device-related harms) associated with AF catheter ablation versus different energy sources in the general adult and Medicare populations?

### Key Points

#### Mortality (all-cause) (within 30 days)

- Paroxysmal: No RCTs were reported. There were no cases reported in either the cryoablation or RFA group during the periprocedural period in two nonrandomized comparative studies (insufficient strength of evidence).
- Persistent, Mixed AF: No data was reported.

#### Stroke (any type) (within 30 days)

- Paroxysmal: No RCTs were reported. There were no cases reported in either the cryoablation or RFA group during the periprocedural period as reported by one small nonrandomized comparative study (insufficient strength of evidence).
- Persistent, Mixed AF: No data was reported.

#### Atrial Fibrillation (within 3 months)

- Paroxysmal: No RCTs were reported. One large nonrandomized comparative study reported similar AF recurrence rates in both groups during the hospitalization period (insufficient strength of evidence).
- Persistent, Mixed AF: No data was reported.

#### Cardiac Tamponade

- Paroxysmal: No RCTs were reported. Periprocedural cardiac tamponade rates ranged from 0.7 to 2.2 percent during cryoablation and from 1.1 to 1.5 percent during RFA based on data from three nonrandomized comparative studies (insufficient strength of evidence).
- Persistent, Mixed AF: No data was reported.

#### Pericardial Effusion

- Paroxysmal: No RCTs were reported. Pericardial effusion occurred in 7.3 to 8.7 percent of cryoablation patients and in 10 to 13.8 percent of RFA patients based on data from two nonrandomized comparative studies (insufficient strength of evidence).
- Persistent: No data was reported.
- Mixed AF: No RCTs were reported. Pericardial effusion occurred in 0 to 1.1 percent of cryoablation patients and in 1.6 to 3.8 percent of RFA patients based on data from two nonrandomized comparative studies (insufficient strength of evidence).

#### Pulmonary Vein Stenosis

- Paroxysmal: No RCTs were reported. There were no cases reported in either group during the periprocedural period in two nonrandomized comparative studies (insufficient strength of evidence).
- Persistent: No data was reported.
- Mixed AF: No RCTs were reported. There were no cases reported in either group during the periprocedural period in one nonrandomized comparative study (insufficient strength of evidence).

### Description of Included Studies

Two RCTs74, 75 and five nonrandomized comparative studies76, 78–81 comparing cryoballoon ablation to RFA reported adverse events. Of the RCTs, one was considered fair quality, included only paroxysmal AF patients and reported periprocedural complications75; the other was considered poor quality, included a mix of paroxysmal and persistent AF patients, and reported complications up to 2 months followup;74 both were small, enrolling 50 and 60 patients each. Of the nonrandomized comparative studies, one was a prospective fair-quality comparative observational study,76 one a poor-quality prospective registry study,81 and three were retrospective poor-quality comparative observational studies.78–80 Of the nonrandomized comparative studies, two were prospective fair-quality comparative observational studies,76, 77 one prospective study was of poor quality,81 and three were retrospective poor-quality comparative observational studies.78–80 Of the comparative observational studies, three included only paroxysmal AF patients76, 80, 81 and two included only paroxysmal AF patients.78, 79 Three of the nonrandomized comparative studies were smaller, reporting on between 124 and 177 patients76, 78, 79 and another was slightly larger, reporting on 396 patients.80 One observational comparative study was registry based and large in size, reporting on 3775 patients.81 The vast majority of adverse events reported in the nonrandomized studies occurred periprocedurally. See Key Question 1b as well as the detailed demographics tables for general study characteristics and additional details (Appendix E, Tables E15–E18).

### Detailed Synthesis

#### Major Adverse Events

##### Mortality (within 30 days)

Neither RCT reported 30-day mortality rates. The two larger retrospective cohort studies both reported no deaths during the periprocedural period following cryoablation or RFA (total N=4171) (Table 29).80, 81

##### Stroke (any type) or Transient Ischemic Attack (within 30 days)

Neither RCT reported 30-day stroke rates. The prospective cohort study reported no strokes following cryoballoon ablation or RFA (N=133); 76 two retrospective cohort studies reported no difference in the risk stroke or transient ischemic attack during the periprocedural period (0–0.3% in both groups, total N=4171) (Table 29).80, 81

##### Myocardial Infarction (within 30 days)

Neither RCT reported 30-day myocardial infarction. One large registry-based comparative study reported no difference in periprocedural myocardial infarction occurrences between patients who received cryoablation and RFA (0.1% vs. 0%, N=3775) (Table 29).81

##### Other Embolic Events

None of the studies reported on any other embolic events.

##### Major Bleeding, Hemorrhage, or Transfusion (within 30 days)

Neither RCT reported 30-day major bleeding events. The large comparative registry study reported a statistically similar risk following cryoablation versus RFA (0.6% vs. 1.1%, p=0.1775; N=3775) (Table 29).81

#### Arrhythmia (within 3 months)

##### Atrial Fibrillation (within 3 months)

Neither RCT reported on AF recurrence within 3 months. One large comparative registry-based study found no difference in AF recurrence rates during the hospitalization period in patients who underwent cryoballoon ablation or RFA (5.9% vs. 5.6%, N=3775) (Table 29).81

##### Other types of Arrhythmia (within 3 months)

One RCT of paroxysmal and persistent AF patients reported that 3 percent (1/30) of cryoablation and 0 percent of RFA (0/30) patients experienced atrioventricular nodal reentrant tachycardia within 3 months; the patient was successfully reablated within 2 months of the original ablation (Table 30).74 One retrospective cohort study reported similar risk of recurrence of any arrhythmia following cryoablation and RFA (0.7% vs. 1.9%, N=396); the same study reported two cases of sinus arrest/third-degree atrioventricular block following RFA (0.8%) and no cases following cryoablation.80 One large observational registry study reported one case of atrioventricular block in the cryoablation group (0.1%) and none in those who received RFA; this study also noted that 0.2 percent of patients in both groups required pacemaker implantation following ablation (Table 29).81 No other arrhythmias were reported within 3 months of the ablation procedure.

#### Ablation-Related Adverse Events

##### Cardiac Tamponade

Neither RCT reported information on cardiac tamponade. Three nonrandomized comparative studies of paroxysmal AF patients found no difference between cryoballoon ablation and RFA groups in the risk of cardiac tamponade (0.7–2.2% vs. 1.1–1.5%, total N=4304) (Table 29).76, 80, 81

##### Pericardial Effusion

Neither RCT reported pericardial effusion rates. Four nonrandomized comparative studies reported pericardial effusion risks.76, 79–81 In the cryoballoon ablation group, rates ranged from 0 to 9 percent; in the RFA groups, rates ranged from 2 to 14 percent (Table 29). Although rates varied across studies, there was no difference in the risk of pericardial effusion between treatment groups in any study.

One RCT reported one case of pericardial pain without effusion following cryoballoon ablation (and none following RFA) (Table 30).74

##### Pulmonary Vein Stenosis

Pulmonary vein stenosis was not reported by either RCT. Across three nonrandomized comparative studies, there were no instances of pulmonary vein stenosis in the periprocedural period following RFA versus cryoballoon ablation (total N=4295) (Table 29).79–81

##### Other Ablation-Related Complications

The most commonly reported other ablation-related complication in studies comparing cryoballoon ablation to RFA was phrenic nerve palsy or diaphragmatic hypokinesia. In general, the data trends suggest that this periprocedural event may be more common during cryoballoon ablation than RFA (Tables 29 and 30). One RCT reported a statistically similar risk of transient phrenic nerve palsy following cryoablation and RFA (7% [2/30] vs. 0% [0/30], p=0.15);74 the other RCT also found that significantly more cryoballoon ablation patients experienced periprocedural diaphragmatic hypokinesia than did RFA patients (16% [4/25] vs. 0% [0/25], p=0.0390).75 Both RCTs reported all cases to be resolved during the procedure. All five nonrandomized studies reported on phrenic nerve palsy. The three studies on paroxysmal AF patients found significantly higher risk of periprocedural phrenic nerve palsy during cryoballoon ablation versus RFA (2.1%–8.1% vs. 0%, p≤0.0164);76, 80, 81 in contrast both observational comparative studies evaluating patients with various types of AF found no difference between treatment groups (0%–2% vs. 0%, respectively).78, 79 One study reported that two (of 11) patients with phrenic nerve palsy did not resolve until 7 and 15 months postprocedure,80 another reported two (of two) cases of this complication did not recover until 3 and 14 months following ablation,78 and one study did not report details regarding resolution of this event.81

Three comparative observational studies reported on atriovenous fistula occurrences resulting from ablation procedures. Across all three studies, there was only one case of this adverse event and it was in a RFA patient (N=4304) (Table 29).76, 80, 81 The patient underwent a vascular intervention and required two additional days in the hospital.

One RCT reported one case of hemoptysis secondary to a hematoma surrounding the right inferior pulmonary vein in a cryoballoon ablation patient (Table 30).75

#### Drug Therapy-Related Adverse Events

One poor-quality retrospective observational study of mixed AF patients (N=124) reported no difference between cryoballoon ablation and RFA groups in the percentage of patients who had renal infarction (1.6% vs. 0%) (Table 29).79 No other drug-related adverse events were described.

#### Peripheral Vascular Complications

Peripheral vascular complications were reported by a total of four studies. One RCT found no difference between cryoballoon ablation versus RFA groups in terms of a major groin hematoma (3% vs. 0%) (Table 30);74 one nonrandomized comparative study reported slightly higher incidence of groin hematoma following cryoballoon ablation versus RFA (1.5% vs. 0%),80 while another cohort study noted similar rates of hematoma at catheter insertion site or pseudoaneurysm was reported by one poor-quality retrospective cohort study (4.8% vs. 4.8%) (Table 29). Femoral pseudoaneurysm occurred in similar percentages of patients between groups as reported by one RCT74 and one nonrandomized comparative study80 (Tables 30 and 29, respectively). One RCT reported a case of femoral arteriovenous fistula requiring surgical repair in the RFA group and none in the cryoballoon ablation group.75 Finally, one registry-based comparative study reported significantly fewer cases of minor bleedings (not requiring intervention) following cryoballoon ablation compared with RFA (2.3% vs. 3.8%, p=0.0336; N=3775) (Table 29).81

#### Other Adverse Events

Neither RCT reported any other adverse events. Three nonrandomized comparative studies reported other adverse events, and there were no differences between treatment groups in the occurrences of any.79–81 Additional events included pneumothorax, hemothorax, significant hypotension, transient ST elevation, and contrast reactions (Table 29).

Of note, the large comparative registry study of 3775 paroxysmal AF patients found that there was a significantly lower overall procedural complication risk (excluding phrenic nerve palsy) in patients treated with cryoballoon ablation than those who received RFA (2.7% [24/905] vs. 4.6% [132/2870], p=0.0103), but no difference between groups in the overall complication risk (4.6% [42/905] vs. 4.6% [132/2870]) (Table 29).81

Table 29 Adverse events for comparative observational studies comparing cryoballoon ablation with RFA

Adverse Event | | AF Type (1^st^/2^nd^ line therapy) | Study | Followup | Cryoablation % (n/N) | RFA % (n/N)
Major Events | Mortality (cardiovascular) <30 days | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0% (0/905) | 0% (0/2,870)
Major Events | Mortality (cardiovascular) <30 days | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 0% (0/136) | 0% (0/260)
Major Events | Mortality (all cause) <30 days | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0% (0/905) | 0% (0/2,870)
Major Events | Mortality (all cause) <30 days | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 0% (0/136) | 0% (0/260)
Major Events | Stroke (any type) <30 days | Paroxysmal (2^nd^ line) | Chierchia 2010^76^ | Periprocedural | 0% (0/46) | 0% (0/87)
Major Events | Stroke/TIA | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.3% (3/905) | 0.3% (9/2,870)
Major Events | Stroke/TIA | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 0% (0/136) | 0% (0/260)
Major Events | Myocardial infarction | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.1% (1/905) | 0% (0/2,870)
Major Events | Major bleeding | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.6% (5/905) | 1.1% (30/2,870)
Major Events | “Major adverse cardiac and cerebrovascular events” | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.4% (4/905) | 0.2% (6/2,870)
Ablation-Related Events^*^ | Cardiac tamponade | Paroxysmal (2^nd^ line) | Chierchia 2010^76^ | Periprocedural | 2.2% (1/46) | 1.1% (1/87)
Ablation-Related Events^*^ | Cardiac tamponade | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.8% (7/905) | 1.4% (37/2,870)
Ablation-Related Events^*^ | Cardiac tamponade | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 0.7% (1/136) | 1.5% (4/260)
Ablation-Related Events^*^ | Pericardial effusion | Paroxysmal (2^nd^ line) | Chierchia 2010^76^ | In-hospital | 8.7% (4/46) | 13.8% (12/87)
Ablation-Related Events^*^ | Pericardial effusion | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 7.3% (10/136) | 10% (26/260)
Ablation-Related Events^*^ | Pericardial effusion | Mixed (1^st^/2^nd^ line) | Mandell 2013^79^ | Periprocedural | 0% (0/62) | 1.6% (1/62)
Ablation-Related Events^*^ | Pericardial effusion | Mixed (2^nd^ line) | Kojodjojo 2010^78^ | Periprocedural | 1.1% (1/90) | 3.8% (2/53)
Ablation-Related Events^*^ | Pulmonary vein stenosis | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.0% (0/905) | 0% (0/2,870)
Ablation-Related Events^*^ | Pulmonary vein stenosis | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 0% (0/136) | 0% (0/260)
Ablation-Related Events^*^ | Pulmonary vein stenosis | Mixed (1^st^/2^nd^ line) | Mandell 2013^79^ | Periprocedural | 0% (0/62) | 0% (0/62)
Ablation-Related Events^*^ | Phrenic nerve palsy | Paroxysmal (2^nd^ line) | Chierchia 2010^76^ | Periprocedural | 6.5% (3/46) | 0% (0/87)
Ablation-Related Events^*^ | Phrenic nerve palsy | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 2.1% (18/905) | 0% (0/2,870)
Ablation-Related Events^*^ | Phrenic nerve palsy | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 8.1% (11/136)^§^ | 0% (0/260)^§^
Ablation-Related Events^*^ | Phrenic nerve palsy | Mixed (1^st^/2^nd^ line) | Mandell 2013^79^ | Periprocedural | 1.6% (1/62) | 0% (0/62)
Ablation-Related Events^*^ | Phrenic nerve palsy | Mixed (2^nd^ line) | Kojodjojo 2010^78^ | Periprocedural | 2.2% (2/90) | 0% (0/53)
Ablation-Related Events^*^ | Atriovenous fistula | Paroxysmal (2^nd^ line) | Chierchia 2010^76^ | Periprocedural | 0% (0/46) | 1.1% (1/87)
Ablation-Related Events^*^ | Atriovenous fistula | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.0% (0/905) | 0% (0/2,870)
Ablation-Related Events^*^ | Atriovenous fistula | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 0% (0/136) | 0% (0/260)
Ablation-Related Events^*^ | Aneurysmal spurium/AV fistula | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.8% (7/905) | 1.1% (33/2,870)
Arrythmia (<3 Months)^†^ | AF recurrence (<30 days) | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | In-hospital | 5.9% (53/905) | 5.6% (161/2,870)
Arrythmia (<3 Months)^†^ | Recurrence of any arrhythmia | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | 3 months | 0.7% (1/136) | 1.9% (5/260)
Arrythmia (<3 Months)^†^ | Sinus arrest/third-degree atrioventricular block | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 0% (0/136) | 0.8% (2/260)
Arrythmia (<3 Months)^†^ | AV block III | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.1% (1/905) | 0.0% (0/2,870)
Drug Therapy-Related Adverse Events^†^ | Renal infarction | Mixed (1^st^/2^nd^ line) | Mandell 2013^79^ | Periprocedural | 1.6% (1/62) | 0% (0/62)
Peripheral Vascular Complications | Groin hematoma | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 1.5% (2/136) | 0% (0/260)
Peripheral Vascular Complications | Hematoma at catheter site or Pseudoaneurysm | Mixed (1^st^/2^nd^ line) | Mandell 2013^79^ | Periprocedural | 4.8% (3/62) | 4.8% (3/62)
Peripheral Vascular Complications | Femoral artery pseudoaneurysm | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 0% (0/136) | 0.8% (2/260)
Peripheral Vascular Complications | Minor bleedings not requiring interventions | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 2.3% (21/905) | 3.8% (109/2,870)
Adverse Events (Not Ablation Dependent)^‡^ | Pneumothorax | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.0% (0/905) | 0.3% (8/2,870)
Adverse Events (Not Ablation Dependent)^‡^ | Hemothorax | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.0% (0/905) | 0.2% (6/2,870)
Adverse Events (Not Ablation Dependent)^‡^ | Sepsis | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.0% (0/905) | 0.0% (1/2,870)
Adverse Events (Not Ablation Dependent)^‡^ | Pulmonary embolism | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.0% (0/905) | 0.0% (1/2,870)
Adverse Events (Not Ablation Dependent)^‡^ | Surgical accident | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.0% (0/905) | 0.1% (3/2,870)
Adverse Events (Not Ablation Dependent)^‡^ | Pacemaker implantation | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 0.2% (2/905) | 0.2% (6/2,870)
Adverse Events (Not Ablation Dependent)^‡^ | Significant hypotension | Mixed (1^st^/2^nd^ line) | Mandell 2013^79^ | Periprocedural | 3.2% (2/62) | 0% (0/62)
Adverse Events (Not Ablation Dependent)^‡^ | Transient ST elevation | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 1.5% (2/136) | 0.8% (2/260)
Adverse Events (Not Ablation Dependent)^‡^ | Contrast reactions | Paroxysmal (2^nd^ line) | Mugnai 2014^80^ | Periprocedural | 0% (0/136) | 0.4% (1/260)
Overall Adverse Events | Overall complication risk | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 4.6% (42/905) | 4.6% (132/2,870)
Overall Adverse Events | Procedural complication risk^††^ | Paroxysmal (2^nd^ line) | Schmidt 2014^81^ | Periprocedural | 2.7% (24/905) | 4.6% (132/2,870)

AF = atrial fibrillation; AV = atrioventricular; RFA = radiofrequency catheter ablation; TIA = transient ischemic attack.

* Denominator is the number of patients who underwent the procedure.

† Analysis based on patients “as treated”.

‡ Adverse events that could occur regardless of whether ablation was performed

§ In 81.8% (9/11) phrenic nerve palsy was resolved before discharge while 18.2% (2/11) patients did not recover until 7 and 15 months.

** Reported as persistent or transient phrenic nerve palsy, 1 patient in the cryoablation group had transient phrenic nerve palsy. The authors report the number of adverse events out of the total number of patients with cryoablation though 20 patients also had RFA.

†† Excluding phrenic nerve palsy; otherwise includes all complications reported in the table for this study.

Table 30 Adverse events for RCTs comparing cryoballoon ablation with RFA

Adverse Event | | AF Type (1^st^/2^nd^ line therapy) | Study | Followup | Cryoablation % (n/N) | RFA % (n/N)
Arrhythmia (<3 Months) | AV nodal reentrant tachycardia | Mixed (2^nd^ line) | Herrera Siklody 2012^74^ | 2 months | 3.3% (1/30) | 0% (0/30)
Ablation-Related Events^*^ | Pericardial pain (no pericardial effusion) | Mixed (2^nd^ line) | Herrera Siklody 2012^74^ | Periprocedural | 3.3% (1/30) | 0% (0/30)
Ablation-Related Events^*^ | Phrenic nerve palsy (transient) | Mixed (2^nd^ line) | Herrera Siklody 2012^74^ | Periprocedural | 6.7% (2/30) | 0% (0/30)
Ablation-Related Events^*^ | Diaphragmatic hypokinesia | Paroxysmal (2^nd^ line) | Perez Castellano 2014^75^ | Periprocedural | 16.0% (4/25) | 0% (0/25)
Ablation-Related Events^*^ | Hemoptysis secondary to a hematoma surrounding the right inferior PV | Paroxysmal (2^nd^ line) | Perez Castellano 2014^75^ | Periprocedural | 4.0% (1/25) | 0% (0/25)
Peripheral Vascular Complications | Groin hematoma | Mixed (2^nd^ line) | Herrera Siklody 2012^74^ | Periprocedural | 3.3% (1/30) | 0% (0/30)
Peripheral Vascular Complications | Femoral pseudoaneurysm | Mixed (2^nd^ line) | Herrera Siklody 2012^74^ | Periprocedural | 3.3% (1/30) | 0% (0/30)
Peripheral Vascular Complications | Femoral arteriovenous fistula requiring surgical repair | Paroxysmal (2^nd^ line) | Perez Castellano 2014^75^ | Periprocedural | 0% (0/25) | 4.0% (1/25)

AF = atrial fibrillation; AV = atrioventricular; PV = pulmonary vein; RCTs = randomized controlled trials; RFA = radiofrequency catheter ablation.

* Denominator is the number of patients who underwent the procedure

## Key Question 3 Are there modifications of efficacy, effectiveness, or harms of catheter ablation versus medical therapy or different energy sources by patient-level characteristics such as age, sex, type of AF, comorbidities, risk for stroke or bleeding events, condition (i.e., patients with significant left ventricular dysfunction/heart failure or patients with significant left atrial enlargement or left ventricular hypertrophy), provider/setting characteristics or technique/approach?

### Key Points

- Evidence was insufficient to draw conclusions on the potential impact of patient or provider characteristics on the efficacy, effectiveness, or harms of catheter ablation as compared with medical therapy or comparing ablation using different energy sources (insufficient strength of evidence).
- Studies conducted in specific subgroups of the population found the following:
  - Rates of 30-day cerebral thromboembolism and pericardial effusion were higher, but not significant, with RFA in patients 70 years or older; no differences were seen at 60 days in freedom from recurrence or adverse events.
  - In patients who were receiving RFA as either first- or second-line treatment for AF, both long- and short-term freedom from recurrence rates favored RFA over medical therapy.
  - In patients with heart failure, across three studies the MLHFQ showed improvement following RFA compared with medical treatment. RFA was associated with improved maintenance of sinus rhythm in two studies and greater freedom from arrhythmia recurrence in the third compared with medical therapy; however, reablation was common. In these studies the rate of major complications following RFA were 4 percent and 15 percent.
  - In patients with Type 2 diabetes, at 12 months quality of life was more improved and more patients were free of recurrence of AF with RFA treatment than with medical therapy.

### Detailed Description

All studies described in this Key Question were included in Key Question 1 and so detailed descriptions of their study designs, populations, and primary and intermediate outcomes are provided in that section. Here we focus on whether these studies provided evidence of modification of efficacy, effectiveness, or harms of catheter ablation by patient-level characteristics, provider/setting, or characteristics of technique/approach. Note that outcomes related to patients with different types of AF (permanent vs. paroxysmal) are contained in the main findings of Key Question 1.

#### Age

None of the studies provided evidence as to how older age modified the effects of the interventions. While no RCTs focused on Medicare patients or included subgroup analyses focusing on patients aged 65 years and older, two comparative observational studies did provide limited data on elderly patients (and thus a Medicare-relevant population).48, 53

A fair-quality, prospective, observational study of 412 consecutively enrolled patients aged 70 years and older (mean age, 75 years) who underwent either ablation (n=153) or medical therapy (n=259).48 Patients were followed for a mean of 60 ± 17 months; the study’s primary endpoints were freedom from AF recurrence and treatment-related adverse events. At 30 days, there were more cerebral thromboembolic events, six (4 strokes and 2 TIAs) versus two (1 stroke and 1 TIA), and cases of pericardial effusion (3 vs. 0) in the RFA group than in the medical therapy group, but neither reached statistical significant (p values 0.058 and 0.056, respectively). After the initial 30 days there were no significant differences between the groups in terms of death, thromboembolic events, MI, major bleeding, or CHF.

A poor-quality, case-control study included 351 matched patients who had undergone catheter ablation (n=146, mean age 67.2 years) or drug treatment (n=205, mean age 66.7 years).53 Patients were followed for a mean 69 ± 27 months. As measured to a mean followup of 69 ± 27 months, there was a statistically lower risk of mortality following RFA compared with medical therapy (3/146 vs. 34/205); authors report an adjusted HR of 4.88 (95% CI 1.44 to 16.53; p=0.001) for medical therapy versus PVAI as the referent, adjusting for AF type and comorbidities.

#### Patients with Heart Failure

While no studies evaluate whether the presence of heart failure modified treatment effect, three small fair-quality RCTs (total N=143) evaluated the comparative efficacy and safety of RFA versus medical therapy in patients with heart failure and persistent AF.37, 39, 40 All three studies enrolled heart failure patients with New York Heart Association (NYHA) class II-IV symptoms and ejection fractions less than 35 percent despite receiving optimal heart failure therapy, with two studies following patients for 6 months and the other for 12 months.

All studies reported on health related quality of life, but found different results. Using the MLHFQ, improvements were seen following RFA in all three studies. Two studies reported statistically significant differences favoring RFA at 6 months; means were different in one study (23.7 versus 47.0, p=0.001)37 and the other provided no data, (p=0.02).39 No statistical difference between groups (6-month change from baseline −5.7 ± 19.7 for RFA vs. −2.8 ± 17.9) were seen in the third trial but tended to favor RFA.40 One trial reporting a difference favoring RFA at 6 months reported that the improvement persisted to 12 months.39 One study reported no difference between groups using the Kansas City Cardiomyopathy Questionnaire (KCCQ) at 6 months, and no difference in functional outcomes using the SF-36.^40^ A second study found a significant difference (p=0.02, no data provided) that was maintained at 12 months (mean 21 ± 19 for RFA vs. 41 ± 21, p=0.02).39 The final recent study also demonstrated a statistically significant difference favoring RFA at 6 months (23.7 versus 47.0, p=0.001).37 The lack of consistency in these findings could be due to inadequate sample sizes.

Two trials reported improved maintenance of sinus rhythm following RFA (50.0%–88.0%) compared with medical therapy (0%–7.7%) at 6 to 12 months39, 40 and the third trial reported similar results concerning freedom from arrhythmia recurrence37 at 6 months (RFA 80.8% vs. medical therapy 0%). Across the three studies, repeat ablation was common and occurred in 34 percent (95% CI 19.3 to 52.6) of patients. Two studies reported peak oxygen consumption, which was significantly better at 12 months following RFA versus medical treatment (p=0.02) in one trial39 and at 6 months (p=0.01) in the other.37

Over 6 months, one study reported that 15 percent of RFA patients (4/27 procedures) experienced a study-defined major procedure-related complications within one week, including cerebrovascular accident, cardiac tamponade, and hospital readmission.40 The second 6-month study, found 4.2 percent of patients in the medical therapy arm suffering intracranial hemorrhage as compared to no patients in the RFA arm.37 In the 12-month study, 4 percent (1/25 procedures) of RFA patients experienced a major complication (cardiac tamponade).39 The single death reported in all studies was deemed unrelated to the procedure.

Because of the inconsistency of these RCTs, and the lack of evidence comparing patients with heart failure as compared to those without we were unable to evaluate the impact of heart failure on the effectiveness of the interventions.

#### Diabetic Patients

One good-quality RCT reported on the effectiveness of RFA in 70 diabetes mellitus type 2 patients. Patients had either paroxysmal or persistent AF, and were followed for 12 months.36 The trial demonstrated a significant improvement in HRQOL in terms of many of the SF-36 subscales in RFA versus medically treated patients. Further, RFA patients also favored RFA in terms of freedom from recurrence of AF (RR 1.87, 95% CI 1.23 to 2.83).

While this RCT suggests a benefit of ablation over medical therapy in patients with diabetes, no studies were identified which evaluated the comparative benefit of the interventions in patients with versus without diabetes which precluded analysis of modification of effect based on this comorbidity.

#### First- Versus Second-Line Treatment

Patients underwent treatment as a first-line therapy in three RCTs35, 42, 46 and as a second-line therapy (i.e., had failed previous medical therapy) in eight RCTs.36, 38, 40, 41, 43–45, 47, 83 The outcomes of these studies were used to explore the impact of patients being treated with ablation as first- versus second-line treatment. Overall, although data were insufficient to test for an interaction, results suggest that RFA was favored in terms of short-term freedom from recurrence regardless of whether patients were treated with first- versus second-line therapy. The figures referenced below are included in the intermediate outcomes section of Key Question 1a and include footnotes indicating which studies are in population undergoing first- and second-line treatment.

Short-term (≤12 months) freedom from recurrence from any arrhythmia in paroxysmal AF patients was reported by four fair-quality RCTs (Figure 4), one of which was a study of first-line therapy and three of which were studies of second-line therapy. The study of first-line therapy favored RFA (RR 3.54, 95% CI 2.48 to 5.06),46 as did the pooled estimate from second-line therapy studies (RR 3.31, 95% CI 2.48 to 4.34).38, 44, 47 All studies that included persistent39, 41, 43 or a mix of paroxysmal and persistent AF36, 45 patients that reported short-term freedom from recurrence similarly reported that this outcome was favored in the RFA group.

Long-term (>12 months) freedom from recurrence of any arrhythmia in was reported by three fair-quality RCTs, all of which included paroxysmal AF patients (Figure 5). Of the two RCTs that included only first-line patients, the pooled estimate favored RFA at 24 months (RR 1.22, 95% CI 1.04 to 1.69).35, 42 Similarly, the single RCT which included only second-line patients found similar results at 48 months (RR 1.29, 95% CI 1.04 to 1.59).83

#### Other Factors

The included studies did not provide data to explore any other additional patient or provider subgroups.