# Methods

The methods for this comparative effectiveness review (CER) follow the methods suggested in the Agency for Healthcare Research and Quality (ARHQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews (available at http://www.effectivehealthcare.ahrq.gov/methodsguide.cfm). The main sections in this chapter reflect the elements of the protocol established for the CER; certain methods map to the PRISMA checklist.27 All methods and analyses were determined a priori.

## Topic Refinement and Systematic Review Protocol

This topic was nominated by Centers for Medicare and Medicaid (CMS) as an update to a previous report published in 2009,^21^ particularly to examine longer-term efficacy of catheter ablation and application to the Medicare population in order to inform CMS policy. The AHRQ Task Order Officer functioned as a liaison between the Evidence-based Practice Center (EPC) and CMS and helped resolve any ambiguities regarding the processes or scope of the project. The EPC drafted the initial Key Questions, Analytic Framework, and inclusion/exclusion criteria and refined them with input from a panel of Key Informants, all of whom were required to disclose any financial or other conflicts of interest prior to participation. The Key Informant panel included experts in cardiology primarily (with specialties in electrophysiology, heart failure, and cardiovascular aging/cardiovascular disease in older adults) and internal medicine; representatives from relevant specialty societies; government representatives (i.e., Department of Veterans’ Affairs, National Heart, Lung and Blood Institute); and a patient advocate. After review from AHRQ, the draft questions and framework were posted for public review in December 2013 for 3 weeks. Following review of the public commentary, the EPC drafted a final topic refinement document which was approved by AHRQ and posted to their Web site. In place of a Technical Expert Panel, CMS provided input to the Key Questions and scope of the report. The final topic refinement document served as the basis for the review protocol with minor changes. Both the final topic refinement document and the systematic review protocol can be found on the AHRQ Web site at http://www.ahrq.gov/research/findings/ta/. The protocol was also registered with the PROSPERO international database of prospectively registered systematic reviews.

## Literature Search Strategy

A research librarian conducted searches for primary studies in the following databases: Ovid MEDLINE^®^ (from 2005 to November 2014), Cochrane Central (J November 2014), and Cochrane Database of Systematic Reviews (from 2005 to November 2014). Searches were limited to a beginning date of January 2005 as there are multiple recent systematic evidence reviews, including good-quality reviews from AHRQ (2013, 2009)21, 22 and the Washington State Health Technology Assessment Program (2013),24 that have addressed aspects of the Key Questions for this current review, with searches conducted through late 2013. Key Informant input during topic refinement confirmed that this was a logical approach. The search strategy was developed based on an analysis of the medical subject headings (MeSH), terms, and text words of key articles identified a priori (the full search strategy is available in Appendix A). Reference lists of included articles and relevant review articles were inspected for relevant publications. All citations were downloaded and imported into an electronic database (EndNote^®^ X7 Thomson Reuters, Philadelphia, PA).

All citations were reviewed independently by two individuals at both the title/abstract and full-text level and differences were resolved by consensus.

### Inclusion and Exclusion Criteria

Criteria for inclusion and exclusion of studies were based on the Key Questions and the populations, interventions, comparators, outcomes, timing, and setting (PICOTS) approach as described in Table 1. Briefly, studies of adult patients with paroxysmal, persistent, or permanent/long-standing atrial fibrillation (AF) treated with catheter ablation were sought. For all Key Questions, the focus was on evidence from comparative studies with the least potential for bias. Comparative observational studies were required to have a minimum of 100 patients to be included. Registry and administrative data studies were considered if inclusion criteria were met. Comparators of interest included medical therapy only (i.e., pharmacological agents for rate or rhythm control) and comparisons of different energy sources for catheter ablation (e.g., radiofrequency vs. cryoablation). Comparisons of different techniques and/or approaches and mapping were beyond the scope of this report and thus were excluded. For Key Question 2, case series that were specifically designed to evaluate harms and/or adverse events following ablation, had a minimum of 1000 patients and at least 80 percent followup were included because all included comparative studies were relatively small in size. Including these large case series of ablation patients allowed for the calculation of risk estimates of adverse events based on a larger number of patients.

For all Key Questions, both long-term (>12 months) and short-term (≤12 months) outcomes were identified in included studies. The primary outcomes listed in the PICOTS table (Table 1) were considered to be the most clinically important and were the focus of reporting, decisions for data pooling and determination of overall strength of evidence. Additional outcomes are reported in the detailed evidence synthesis sections of the Key Questions with a focus on outcomes common across studies. Where applicable and where data were available, results from short-term (≤12 months) and long-term (>12 months) followup were described.

Studies published only as conference abstracts, non-English-language articles, and studies of nonhuman subjects were excluded. Studies had to report original data to be included.

Table 1 Summary of inclusion and exclusion criteria

PICOTS Element | Inclusion Criteria | Exclusion Criteria
Population | For all KQs:; - Adult patients (age ≥18 years) with AF (long-standing, persistent, or paroxysmal); - Medicare population ( ≥65 years of age; or <65 years of age and permanently disabled) | - Patients <18 years of age with isolated atrial flutter, isolated atrial tachycardia, AV nodal reentrant tachycardia or AV reentrant tachycardia, focal junctional ectopic tachycardia and nonparoxysmal junctional tachycardia, ventricular tachycardia and paroxysmal ventricular tachycardia, bradycardia; - Patients in whom treatment of AF is not the primary goal, with prior catheter ablation, or who have known reversible causes of AF (including but not limited to postoperative, postmyocardial infarction, hyperthyroidism)
Interventions | - For all KQs: Catheter ablation using devices available for use in the U.S., including ablation methods using different energy sources. Any FDA-approved devices (or devices in final stages of approval) that were used for catheter ablation in patients with AF were included whether or not they have been specifically approved for treatment of AF. | - Use of non-FDA approved devices or devices not in final stages for FDA approval (except as noted above),; - Ablation as an adjunct to surgery or intraoperative ablation, surgical ablation, right atrial ablation for atrial flutter, ablation in which PV electrical isolation is not the goal, or complete AV node ablation requiring pacemaker implantation
Comparators | - For all KQs:; - Medical therapy only, including pharmacological agents for rate control (beta-blockers, nondihydropyridine calcium channel blockers), or pharmacological agents for rhythm control (amiodarone, disopyramide, dofetilide, dronedarone, flecainide, propafenone, sotalol); - Comparison of different energy sources for catheter ablation (e.g., radiofrequency vs. cryoablation) | - Uncontrolled or pre-post studies; - Comparisons of different techniques used in catheter ablation (i.e., use of imaging, types of catheter tips, hybrid strategies); Comparisons of different approaches used in catheter ablation with each other (e.g., PVI vs. PVI plus additional catheter lines); - Diagnostic evaluations, sand studies focused on mapping or those comparing mapping techniques; - Cardioversion alone (i.e., in the absence of antiarrhythmic medical therapy); - Cox-Maze procedure; surgical ablation; - Antiarrhythmic agents: quinidine, procainamide
Outcomes | - For KQs 1, 3: Primary efficacy/effectiveness: prevention of mortality or other serious adverse events, improvement of symptoms, quality of life or functional status.; - For KQs 1, 3: Intermediate outcomes: freedom from recurrence of AF, maintenance of sinus rhythm, repeat ablation for AF, parameters suggesting reverse remodeling, effect on biomarkers, health care utilization (hospitalization/ readmission for cardiovascular events), reduced medication use; - For KQs 2, 3: Harms or adverse events (procedure or pharmacologic treatment related): in hospital and 30-day mortality, stroke, TIA, embolic events, myocardial infarction, other procedural complications, arrhythmias potentially secondary to catheter ablation (within 3 months of procedure), adverse events from drug therapies, hemorrhage, radiation exposure | - Nonclinical outcomes
Timing | - None | - None
Setting | - For all KQs: No restrictions (inpatient and outpatient) | - None
Study design | For KQs 1, 2:; - RCTs or controlled cohort studies, focus was on evidence from comparative studies with the least potential for bias; Comparative observational studies required to have a minimum of 100 patients; For KQ 2:; - Case series or uncontrolled observational studies were considered in the evaluation of harms if they were specifically designed to evaluate adverse events, had a minimum of 1000 patients and a followup of at least 80%; For KQ 3: RCTs | - Nonclinical studies of technique, studies reporting only on technical aspects of ablation, uncontrolled observational studies, nonsystematic reviews, narrative reviews, abstracts, editorials, letters, white papers, articles identified as preliminary reports when results are published in later versions, case series, case-reports
Publication | - Studies published in English in scholarly journals, published health technology assessments, or publicly available FDA reports; - Gray literature (e.g., ongoing or unpublished clinical trial data) | - Studies with a publication date prior to 2005 (to exclude outdated technologies); - Single site reports from multicenter trials; - Duplicate publications of the same study which do not report on unique outcomes or time points

AF = atrial fibrillation; AV = atrioventricular; FDA = U.S. Food and Drug Administration; KQ = Key Question; PV = pulmonary vein; PVI = pulmonary vein isolation; RCT = randomized controlled trial; TIA = transient ischemic attack.

### Study Selection

Abstracts for all citations from the literature searches were independently reviewed by two team members and results were recorded in EndNote. All citations found to be potentially appropriate for inclusion by either reviewer underwent full-text review. Each full-text article was independently evaluated for final inclusion by two investigators. For inclusion, both reviewers had to agree that inclusion criteria were met. Differences between reviewers were resolved through consensus and discussion. A record of studies excluded at the full-text level with reasons for exclusion is included in Appendix C.

### Data Extraction

After studies were selected for inclusion, a total of five experienced team members trained in using the Systematic Review Data Repository (SRDR) database (AHRQ, Rockville, MD; accessed at http://srdr.ahrq.gov/) entered data. After data extraction, at least one other staff member and one investigator each verified the accuracy and completeness of abstraction for each study included. Discrepancies were resolved by discussion and consensus. SRDR was used to maintain the data and to create detailed evidence tables and summary tables.

Reviewers extracted information on general study characteristics (e.g., study design, study period, followup, study setting, funding, and authors’ conflicts of interest), study patients (patients approached/eligible/enrolled, age, sex, comorbidities, echocardiographic parameters), treatment arm details (patients treated, patients with followup, first-/second-line therapy, pharmacologic dose, ablation technique and procedural details, imaging performed), outcome measures, adverse events, and information related to study quality. Outcome measures and adverse events were prespecified during the creation of the extraction form to maintain consistency in data reporting. However, unique results were added during the abstraction process as needed. Special care was taken in the abstraction of information regarding crossover, the blanking period, reablation, and risk of bias. For harms attributable to ablation but not medical therapy (e.g., cardiac tamponade), data were reported on an as-treated basis in order to include data from patients who crossed over from medical therapy to ablation. Basic information regarding technique, approach, provider and setting was also abstracted when reported in included studies. Limited data were extracted from case series with a focus on safety outcomes of interest. An outline of the specific information included in the data extraction forms are available in Appendix D and detailed evidence tables are included in Appendix E. Tables are organized in order of comparison: radiofrequency ablation (RFA) versus medical therapy (Tables E1–E12), cryoballoon ablation versus medical therapy (Tables E13–E14), and studies comparing ablation with different energy types (Tables E15–E18). Within each comparison of interest, there are separate tables for randomized controlled trial (RCT) and observational data, which are further separated by the different atrial fibrillation (AF) patient populations: those with paroxysmal AF, those with persistent AF, and mixed populations.

## Quality Assessment of Individual Studies

Predefined criteria were used to assess the quality (risk of bias) of included RCTs and observational studies by using clearly defined templates and criteria as appropriate and following guidance from the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.28 Assessment of RCTs followed appropriate criteria and methods established in the Cochrane Handbook for Systematic Reviews of Interventions.29 Comparative observational studies were assessed for study design features and sources of potential bias. Briefly, the quality of each comparative study was rated based on the following: methods used for randomization (RCTs only, requirement of computer-generated random numbers, random numbers tables, coin toss, or opaque sequentially numbered envelopes), allocation concealment (RCTs only, requirement of sealed opaque envelopes, centralized randomization, on-site computer based system with a randomization sequence that is not readable until allocation, or blocked randomization), intention-to-treat analysis (RCTs), independent or blind outcome assessment, acceptable attrition (≤20%), comparable attrition between treatment groups (≤20% difference between groups), controlling for possible confounding, full reporting on prespecified outcomes, and whether patients were blinded to treatment received. These criteria and methods were used in concordance with the approach recommended in the chapter, Assessing the Risk of Bias of Individual Studies When Comparing Medical Interventions, in the AHRQ Methods Guide Methods Guide for Effectiveness and Comparative Effectiveness Reviews, wherein each study was rated as being “good”, “fair” or “poor” quality.30 Two investigators independently assessed the quality of each study and any discrepancies were resolved through discussion and consensus.

Studies rated “good” are considered to have the least risk of bias, and their results are considered valid. Good-quality studies include clear descriptions of the population, setting, interventions, and comparison groups; a valid method for allocation of patients to treatment; low dropout rates and clear reporting of dropouts; appropriate means for preventing bias; and appropriate measurement of outcomes.

Studies rated “fair” are susceptible to some bias, though not enough to invalidate the results. These studies may not meet all the criteria for a rating of good quality, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems. The fair-quality category is broad, and studies with this rating will vary in their strengths and weaknesses. The results of some fair-quality studies are likely to be valid, while others may be only possibly valid.

Studies rated “poor” have significant flaws that imply biases of various types that may invalidate the results. They have a serious or “fatal” flaw in design, analysis, or reporting; large amounts of missing information; discrepancies in reporting; or serious problems in the delivery of the intervention. The results of these studies are least as likely to reflect flaws in the study design as the true difference between the compared interventions. Studies rated as being poor in quality a priori were not excluded, but considered to be less reliable than higher-quality studies when synthesizing the evidence, particularly if discrepancies between studies were present.

Each study evaluated was dual-reviewed for quality by two team members. Any disagreements were resolved by consensus. The final risk of quality assessments are described in detail in Appendix F (Tables F1–F5).

## Data Synthesis

When adequate data were reported in studies, meta-analysis was conducted in order to provide more precise estimates for outcomes. To determine the appropriateness of conducting meta-analysis, clinical and methodological diversity and assessed statistical heterogeneity were considered. A random-effects model was used to combine risk ratios for binary outcomes, mean differences for continuous outcomes (e.g., SF-36), and proportions of adverse events that only occurred in the ablation arm, while incorporating variation among studies. For proportions of adverse events, a generalized linear random effects model was used due to sparse data with zero or small number of events. Random effects across studies were assumed and heterogeneity among the studies was tested based on the random effect variance (τ^2^). Otherwise, a profile-likelihood model was used to combine studies,31 and the presence of statistical heterogeneity among the studies was assessed using the standard Cochrane’s chi-square tests and the magnitude of heterogeneity by using the I^2^ statistic.32

To reduce the potential impact of clinical heterogeneity, analyses were stratified by type of AF (paroxysmal, persistent, or mixed population) and length of followup (>12 months vs. ≤12 months). Sensitivity analyses were conducted to assess the robustness of results in regards to treatment type (first-line vs. second-line therapy) across all types of atrial fibrillation. For continuous outcomes, results using the mean differences between followup scores were reported as they are slightly more conservative33 and as the results based on mean difference in change score were similar. The number of studies was too small for exploring heterogeneity based on study level characteristics (aggregated patient characteristics, comorbidities, quality indicators, etc.). All analyses were performed using Stata/IC 12.1 (StataCorp, College Station, TX) and SAS 9.3 (SAS Institute Inc., Cary, NC).

The outcomes listed below were considered to be the most relevant and were the focus of reporting, data pooling, and determination of overall strength of evidence. Mortality, stroke, and myocardial infarction (MI) occurring after the 30-day peri-procedural period were considered to be efficacy or effectiveness outcomes while such events occurring within the 30 day peri-procedural period were considered adverse events. Primary outcome measures of interest included: mortality (all cause) >30 days post procedure, stroke (>30 days), MI (>30 days), congestive heart failure, and health-related quality of life. Intermediate outcome measures of interest included: freedom from recurrence, maintenance of sinus rhythm, and reablation for any arrhythmia (one or more repeat procedures). Primary safety outcomes of interest included: AF (<3 months), mortality (<30 days), stroke (<30 days), cardiac tamponade, pericardial effusion, pulmonary vein stenosis, and adverse drug events. Outcomes such as pulmonary vein stenosis, cardiac tamponade, and pericardial effusion were considered to be attributable to ablation.

Continuous outcome measures reported in this review include: health-related quality of life (HRQOL) questionnaires, exercise capacity (e.g., 6-minute walk test, stress tests), cardiac chamber size/function (e.g., left atrium [LA] enlargement, left ventricle [LV] enlargement, left ventricular ejection fraction [LVEF]), biomarkers (e.g., brain natriuretic peptide [BNP], coagulation, and inflammatory markers), and AF burden. Of the eight HRQOL measures reported, four were specific to populations with heart disease (Atrial Fibrillation Quality of Life [AF-QOL], Kansas City Cardiomyopathy [KCCQ], Minnesota Living with Heart Failure Questionnaires [MLHFQ], and the Symptom Checklist Frequency and Severity Scales) and four were general surveys of health status (Short Form-36 [SF-36], European Quality of Life-5 Dimensions [EQ-5D], Zung Self-Rating Depression Scale [SDS], and Zung Self-Rating Anxiety Scale [SAS]). All questionnaires were self-administered and all but one (MLHFQ) are scored so that higher scores reflect better health status (see Appendix H, Table H1 for details). The SF-36 was the most frequently reported HRQOL measure, in particular the SF-36 Mental Component Score (MCS) and the SF-36 Physical Component Score (PCS). Repeat ablations (i.e., reablation for arrhythmia recurrence) were included as an intermediate outcome only if they occurred after the blanking period, which was typically 4 to 6 weeks. Outcomes were reported as defined and definitions have been clarified as needed throughout the report. Detailed descriptions of these outcomes are available in the study characteristics tables in Appendix E. Some outcomes, particularly adverse events such as cardiac tamponade and pericardial effusion, are attributed to ablation, thus denominators for these outcomes reflect only patients who received ablation (either as randomized or after crossover from medical therapy).

## Strength of the Body of Evidence

The strength of evidence for each primary efficacy/effectiveness and safety outcome described above was initially assessed by one researcher using the approach described in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews, also available from the AHRQ Web site.28, 30

In determining the strength of a body of evidence regarding a given outcome, the following domains are considered:

- Study limitations: the extent to which studies reporting on a particular outcome are likely to be protected from bias; graded as low, medium, or high level of study limitations
- Consistency: the extent to which studies report the same direction of effect for a particular outcome; graded as consistent, inconsistent, or unknown (in the case of a single study)
- Directness: reflects whether the outcome is directly or indirectly related to health outcomes of interest
- Precision: describes the level of certainty of the estimate of effect for a particular outcome and includes consideration of the sample size and number of events; graded as precise or imprecise
- Reporting bias: suspected if there was evidence of selective reporting, otherwise considered to be undetected.

A final strength of evidence grade was assigned by evaluating and weighing the combined results of the above domains; final grades are presented in the Discussion, and tables detailing how final grades were determined are available in Appendix G. To ensure consistency and validity of the evaluation, the strength of evidence ratings for all key outcomes were reviewed by the entire team of investigators, and discrepancies were resolved by consensus.

Briefly, bodies of evidence consisting of RCTs started as high strength while bodies of comparative observational studies began as low-strength evidence. The strength of the evidence was then downgraded based on the limitations described above. There are also situations where the observational evidence may be upgraded (e.g. very large size of effect), but we found no instances where these could be applied in this body of evidence (see AHRQ’s Methods Guide for details on upgrading). The overall grades and their definitions are as follows:

- High — We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
- Moderate — We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
- Low — We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient — We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## Applicability

Applicability of the evidence was considered by examining the characteristics of the patient populations included in studies (e.g., demographic characteristics, type of AF, presence of medical comorbidities, stroke risk); the sample size of the studies; and clinical settings (e.g., academic setting, provider experience) in which the studies are performed, as outlined in the AHRQ Methods Guide.28, 34 Variability in the studies may limit the ability to generalize the results to other populations and settings, for example studies enrolling relatively younger patients with few comorbidities may be less applicable to older patients (i.e., those in the Medicare population).

## Peer Review and Public Commentary

Experts in atrial fibrillation and catheter ablation as well as individuals representing other important stakeholder groups were invited to provide external peer review of this Technology Assessment. Comments and editorial review were provided by the AHRQ Task Order Officer. The draft report will be published on the AHRQ Web site for 2 weeks in order to solicit public comments. At the end of this period, the authors considered both the peer and public review comments and generated a final report. A disposition of comments report detailing the author response to the peer and public review comments will be made available after AHRQ posts the final report on the public Web site.