# Introduction

## Background

### Nature and Burden of Atrial Fibrillation

Atrial fibrillation (AF) is a major public health concern in the United States, affecting an estimated 2.3 million Americans.1 The prevalence of AF is projected to reach 5.6 to 12.1 million by the year 2050.^2^ AF is the most common sustained arrhythmia seen in clinical practice and accounts for approximately one third of hospitalizations for cardiac dysrhythmias.3

AF is characterized by uncoordinated atrial activation with resulting deterioration of atrial mechanical function.4 While AF can occur in isolation, it may also be associated with other arrhythmias such as atrial flutter or atrial tachycardia. Atrial fibrillation can be paroxysmal, persistent, or permanent. The 2014 American College of Cardiology/American Heart Association/Heart Rhythm Society AF guidelines4 define paroxysmal AF as recurrent AF that terminates spontaneously or with intervention within 7 days of onset, persistent AF as one that is sustained beyond 7 days, and permanent AF as long-standing AF in which restoring and/or maintaining sinus rhythm has failed or has been foregone. Long-standing persistent AF is usually defined as AF that persists for over a year. Long-standing persistent and permanent AF are more commonly seen in older patients with structural heart disease.

A number of factors have been associated with increased risk of AF. The prevalence of AF increases with age; it affects 8 to 10 percent of patients 80 years of age and over.2, 5, 6 AF is also more common in males: data from the Framingham Heart Study suggest that men are 1.5 times as likely to develop AF than are women after controlling for age and comorbidities.2 Obesity increases the risk of developing AF. Data from community-based cohorts suggest that obese patients have a 1.5- to 2.3-fold greater risk of developing AF. Furthermore, obesity increases the likelihood that AF will progress from paroxysmal to permanent AF.6 Additional factors that have been associated with an increased risk of AF include smoking, hypertension, hyperthyroidism, obstructive sleep apnea, diabetes, myocardial infarction, heart failure, and cardiac surgery.6

AF is associated with significant mortality, morbidity, and health care costs. Patients with AF have a twofold greater risk of death than do those without this disease. AF is associated with an increased risk of stroke, which affects 5 percent of nonrheumatic AF patients and nearly 7 percent of AF patients with heart failure each year.7 Furthermore, ischemic stroke that occurs in the setting of AF tends to be either fatal or of moderate to high severity in most patients.8 AF can also cause a number of cardiac conditions, including myocardial ischemia or infarction, exacerbation of heart failure, and cardiomyopathy if the ventricular rate is insufficiently controlled.9–12 Although some patients with AF are asymptomatic, other patients experience symptoms like shortness of breath, intractable fatigue, and near-syncope, which can severely affect overall quality of life.13–16 In total, the management of AF and its complications costs the U.S. health care system approximately $26 billion each year.4, 17

### Management of Atrial Fibrillation

Treatment of AF involves rate control, rhythm control, prevention of thromboembolic events, and treating the underlying disease (e.g., hypertension) if applicable.4 Typically, pharmacologic therapy is the primary treatment for rate and rhythm control, while pulmonary vein isolation with catheter ablation is reserved for second-line treatment but may be appropriate as a first-line treatment in select populations when a rhythm control strategy is desired.4 Discussion of strategies to prevent thromboembolic events or to treat underlying causes of AF are beyond the scope of this report.

While the initial management of AF often includes control of ventricular rate using pharmacological agents (i.e., beta-blockers or nonhydropyridine calcium channel blockers), it is common for the long-term management strategy to focus on restoring and maintaining normal heart rhythm.4 AF patients who continue to have significant symptoms despite adequate rate control or who desire long-term rhythm control may be considered for treatment using a rhythm control strategy.

#### Pharmacological Rhythm Control

The primary reason for rhythm control in patients with AF is to improve symptoms. In some patients, adequate rate control is enough to control symptoms, but if patients continue to have symptoms despite good rate control, then rhythm control should be considered. In the absence of symptoms, rhythm control can be used in patients with rapid ventricular response to AF when rate controlling medications are ineffective or cannot be tolerated. Rhythm control should not be used to allow patients to come off anticoagulation as the decision regarding anticoagulation should be based on their risks of thromboembolic events and bleeding.4 Pharmacologic therapy is typically the first choice. Selection of the first-line antiarrhythmic medication is largely driven by the presence or absence of structural heart disease. For example, the 2014 Guidelines for the Management of Patients with Atrial Fibrillation give a Class I recommendation for treatment with flecainide, dofetilide, propafenone, dronedarone, sotalol and amiodarone; but for amiodarone, the guidelines emphasize that because of its potential toxicities, it should only be used after consideration of risks and when other agents have failed or are contraindicated. In patients with heart failure, the guidelines recommend one of two antiarrhythmic medications as first-line therapy (dofetilide and amiodarone).4 Side effects can occur with the use of antiarrhythmic medications; some may actually cause more arrhythmias, and some may lose effectiveness over time. Patients on these medications therefore need to be monitored to assess the impact of medications on heart rhythm and the potential for side effects and interactions with any concomitant medications such as anticoagulants.

#### Catheter Ablation Rhythm Control

Catheter ablation for the treatment of AF is increasingly being performed on symptomatic patients as an alternative to medical management, or when medical management has been ineffective or not tolerated.18–20 AF ablation is typically recommended only for symptomatic patients; asymptomatic patients are usually managed with anticoagulation and/or rate control as needed.4 The outcomes of this procedure may depend on patient characteristics such as age, AF type, and presence of structural heart disease, as well as on experience of the operator and methods and technologies used during the procedure. Relief of symptoms is a primary reason for considering catheter ablation as a treatment strategy.

In catheter ablation, energy is sent through an electrode at the tip of a catheter into specific areas of the heart to destroy (ablate) or electrically isolate small areas of tissue where abnormal electrical signals that trigger abnormal heart beats originate. The goal of catheter ablation for treatment of AF is to ablate or isolate triggers that mostly originate in the area of the pulmonary veins. Thus, the most commonly used and recommended catheter ablation procedure to treat AF is pulmonary vein isolation (PVI).18, 21 For the procedure to be successful, complete bi-directional electrical isolation of all pulmonary veins should be achieved. While other approaches may also be used, typically in addition to PVI, there is uncertainty regarding additional benefits or harms of such approaches.18 Recent systematic reviews attempted to evaluate the efficacy of approaches relative to each other,22–24 but significant heterogeneity with regard to the approaches compared precluded meaningful conclusions.22

Among methods and technologies used during the procedure, energy source is an important factor. Currently, there are two US Food and Drug Administration (FDA)-approved options for catheter ablation: radiofrequency energy, which heats the target sites, and cryoablation, which cools/freezes the sites. Cryoablation may be performed using either a focal catheter-tip (as in radiofrequency ablation) or a balloon catheter. Balloon catheters can ablate larger areas of abnormal tissue than single tip catheters which involve point-by-point application of energy. How cryoablation including use of a balloon catheter for ablation compares with traditional radiofrequency ablation in relation to efficacy and safety is also uncertain and is the subject of ongoing debate.

Imaging may be performed before or during the procedure, including magnetic resonance imaging, computed tomography imaging, and transthoracic, trans-esophageal, and intra-cardiac echocardiography. Electroanatomic mapping, which allows for a real-time three-dimensional view of the heart, is often used during the procedure to look for triggers of AF, confirm successful ablation, and allow characterization of its impact on overall left atrial (LA) function. Mapping techniques vary greatly and continue to evolve. Two examples of mapping systems available for use in clinical practice are CARTO (Biosense Webster Inc., CA, USA) and EnSite NavX (St. Jude Medical Inc., MN, USA). The comparative benefits or harms of these techniques are unclear as to date they have not been evaluated in a randomized controlled trial (RCT). Evaluation of imaging and mapping approach is beyond the scope of this report.

Three catheter ablation devices have been approved by the FDA for use in AF patients (see Appendix H; Table H5), with the first approved in 2009. One device employs radiofrequency energy and utilizes an irrigated catheter tip of 3.5 mm (Biosense Webster), while the other two are cryoablation catheters that use a balloon with a diameter of 23 to 28 mm (Medtronic Cryocath). A number of other radiofrequency ablation (RFA) and cryoablation catheter devices have been approved for the treatment of other types of arrhythmia and may be used “off-label” for the treatment of AF.

## Scope and Key Questions

In 2009, AHRQ published a comparative effectiveness review that evaluated both clinical effectiveness and harms of RFA for AF.21 At that time, only six RCTs enrolling a total of 693 patients were available. There was moderate-strength evidence that patients treated with RFA after failing medical therapy had a threefold greater likelihood of maintaining freedom from AF recurrence at 12 months compared with patients who received medical therapy alone. There was low strength evidence that RFA resulted in greater quality of life and less need for anticoagulation but no difference in the risk of stroke and the rate of readmission. High strength evidence indicated that age wasn’t significantly associated with AF recurrence after ablation; however, most patients studied were in their fifties (age range, 40 to 70 years) and the evidence was insufficient to estimate whether older age affected outcomes. At the time of the 2009 report, evidence was lacking for a number of issues, including health outcomes beyond 1 year, whether ablation reduces the risk of death and stroke, and the comparative effectiveness and harms of catheter ablation in the Medicare population (≥65 years of age; or <65 years of age and permanently disabled). The 2009 report did not compare cryoablation with medical therapy or compare catheter ablation energy sources with one another.

Based on Medicare Provider Analysis and Review (MedPAR) files, use of catheter ablation for the treatment of AF in the Medicare population increased substantially between 2001 and 2006 from an annual total procedural volume of 135 to 1975 cases and an increase in the number of hospitals performing RFA from 100 to 162.^25^ Annual complication rates increased from 6.7 to 10.1 percent during the same time period, but increasing age was not associated with a higher rate of complications. Procedural volume was associated with probability of in-hospital death but not with overall risk of complications. An almost two-fold increase in the number of patients treated with catheter ablation was reported between 2003 and 2006 compared with the number treated between 1995 and 2002 based on a world-wide survey of electrophysiology centers.26 The authors also report that catheter ablation was increasingly being offered to sicker AF patients. Catheter ablation was reported to be effective in approximately 80 percent of patients. A risk of 4.5 percent for major complications was also reported. Anecdotally, utilization has continued to increase in the Medicare and general populations.

Since the publication of the 2009 AHRQ report, the Catheter Ablation versus Anti-arrhythmic Drug Therapy for Atrial Fibrillation (CABANA) Trial was initiated to directly compare various methods of catheter ablation with medical therapy in a large, multi-center, multi-national trial that includes older patients (over 60 years old) with paroxysmal and persistent AF (ClinicalTrials.gov identifier NCT00911508); however, final data collection for the primary outcome measure will not be completed until September 2017.

Because there is increasing use of catheter ablation to treat AF patients in the Medicare population as well as uncertainty regarding the efficacy and harms of this procedure in this population in particular, and given that results from CABANA will not be available until 2018 at the earliest, the Centers for Medicare and Medicaid (CMS) has partnered with AHRQ to commission this systematic review to evaluate the current state of comparative evidence, with the aims of informing clinical practice and policy and to providing insight into research needs and general approaches for addressing identified evidence gaps.

### Key Questions

The objectives of this review include evaluating the comparative efficacy, effectiveness, and safety of catheter ablation and medical therapy for the treatment of AF. For the purposes of this report, efficacy refers to the ability of a treatment to produce a desired effect under optimum controlled conditions, such as during a randomized controlled trial. Effectiveness refers to the effect of treatment in actual clinical practice as evaluated by observational studies or comparative pragmatic trials. Comparative effectiveness review is a general term and in this report refers to the conduct and synthesis of systematic research to compare the interventions of interest, incorporating information on efficacy from RCTs and on effectiveness from comparative observational studies. Comparative effectiveness also includes evaluation of adverse events and harms. The Key Questions to be explored are as follows:

Key Question 1. What is the comparative efficacy and effectiveness of AF catheter ablation on short-term (6–12 months) and long-term (>12 months) outcomes in the general adult and Medicare populations? Comparisons of interest include:

a. Catheter ablation compared with medical therapy
b. Comparing ablation using different energy sources

Key Question 2. What are the comparative short- and long-term complications and harms (e.g., periprocedural or device-related harms) associated with AF catheter ablation in the general adult and Medicare populations? Comparisons of interest include:

a. Catheter ablation compared with medical therapy
b. Comparing ablation using different energy sources

Key Question 3. Are there modifications of efficacy, effectiveness, or harms of catheter ablation by patient-level characteristics such as age, sex, type of AF, comorbidities, risk for stroke or bleeding events, condition (i.e., patients with significant left ventricular dysfunction/heart failure or patients with significant left atrial enlargement or left ventricular hypertrophy), provider/setting characteristics or technique/approach? Comparisons of interest include:

a. Catheter ablation compared with medical therapy
b. Comparing ablation using different energy sources

### Analytic Framework

The analytical framework for the systematic review is presented in Figure 1. This figure depicts the Key Questions addressed in this review. In general, the figure illustrates how the treatments relate to the outcomes and how the outcomes relate to each other. For example, a patient (far left of diagram) presents with AF and may receive medical therapy or catheter ablation (radiofrequency or cryoablation). The treatment can lead to long-term health outcomes (far right of the diagram), intermediate outcomes and harms. The solid lines marked with Key Question numbers represent the questions that this review will evaluate in a comparative way (intervention vs. intervention). The dotted line represents the evidence of a relationship between intermediate and health outcomes (which is beyond the scope of this review). The bottom box represents Key Question 3, which examines evidence on variation in outcome based on specific patient characteristics.

Figure 1 Analytic framework for catheter ablation for atrial fibrillation

* Patients with longstanding persistent atrial fibrillation, persistent atrial fibrillation, or paroxysmal atrial fibrillation (considered separately); includes general population and Medicare population.

†Intermediate outcomes are those which may be along the causal pathway to final health outcomes.

BNP = brain natriuretic peptides; HRQOL = health-related quality of life; LA = left atrium; LV = left ventricle; LVEF = left ventricular ejection fraction.

Figure 1. This figure, referred to as the analytical framework, depicts the Key Questions addressed in this review. In general, the figure illustrates how the treatments relate to the outcomes and how the outcomes relate to each other. For example, a patient (far left of diagram) presents with atrial fibrillation and may receive medical therapy or catheter ablation (radiofrequency or cryoablation). The treatment can lead to long-term health outcomes (far right of the diagram), intermediate outcomes and harms. The solid lines marked with Key Question numbers are those that this review will evaluate in a comparative way (intervention versus intervention). The dotted line represents the evidence of a relationship between intermediate and health outcomes and is beyond the scope of this review. The bottom box represents Key Question 3, where evidence on variation in outcome based on specific patient characteristics is examined.