# Conclusions

Evidence was insufficient to draw conclusions on the efficacy, effectiveness, and harms of catheter ablation for atrial fibrillation (AF) specific to the Medicare population. In the general population, conclusions regarding the long-term efficacy of catheter ablation to impact primary clinical outcomes are limited; in those with paroxysmal AF, strength of evidence was low that there is no difference between radiofrequency ablation (RFA) and medical therapy in all-cause-mortality. Low strength of evidence means that there is limited confidence that the effect estimate is close to the true effect. Evidence from RCTs was insufficient for no differences in stroke, myocardial infarction (MI) and chronic heart failure (CHF) after 12 months. Although observational studies may suggest lower stroke and heart failure risk following RFA versus medical therapy, the evidence was insufficient. In the short term, strength of evidence was low that there were no differences between treatments for all-cause mortality and MI and insufficient for stroke and CHF, regardless of AF type. No overall conclusions can be drawn regarding the impact of RFA on health-related quality of life across studies. In patients with heart failure and persistent AF, low strength of evidence suggests quality of life may be improved following RFA up to 6 months. No long-term randomized controlled trial (RCT) data in those with persistent AF for the primary outcomes of mortality, stroke, MI, or development of CHF were identified. For intermediate outcomes, moderate strength of evidence indicates that RFA is superior to medical therapy for enhancing patient freedom from recurrence of atrial arrhythmias in the short term in those with paroxysmal AF and appears to be sustained for the longer term. Strength of evidence was low for freedom from recurrence in those with persistent AF in the short term and insufficient in the longer term. Regarding harms, there was low strength of evidence for no difference between RFA and medical therapy in 30-day mortality or 30-day stroke. There was low strength of evidence that there was no difference between RFA and medical therapy in 3-month risk of AF in paroxysmal AF patients, but data from two trials of persistent AF patients suggested significantly lower risk of 2- to 3-month AF recurrence following RFA versus medical therapy (low strength of evidence). Risk estimates for cardiac tamponade following RFA were imprecise; the strength of evidence was low regardless of AF type. There is insufficient evidence comparing cryoballoon ablation with medical therapy for outcomes other than freedom from protocol defined treatment failure which favored cryoballoon ablation. There is insufficient evidence comparing cryoballoon ablation versus RFA to draw conclusions regarding efficacy or safety. In order to better understand the impact that catheter ablation has on key health outcomes such as stroke, mortality, quality of life, and symptom improvement in comparison to other AF treatment strategies, additional large methodologically sound studies are needed. Such studies are particularly needed on persistent AF patients, as well as on those in the Medicare population. Furthermore, studies with sufficient sample sizes are needed in order to effectively determine whether catheter ablation versus other treatment options will benefit certain patient subgroups more than others, including those for whom catheter ablation might best used as a first-line versus second-line treatment strategy.

In summary, there was insufficient evidence to draw conclusions regarding the efficacy, effectiveness and safety of catheter ablation in the Medicare population. In the general population, there is moderate evidence that RFA is superior to medical therapy for enhancing patient freedom from recurrence of atrial arrhythmias in both the short and long term regardless of AF type, but reablation is common. RFA does not appear to impact all-cause mortality in the short or long term in those with paroxysmal AF (low strength of evidence); however, there is insufficient evidence to draw conclusions regarding other primary clinical outcomes in the short or long term. Firm conclusions regarding health-related quality of life are not possible given heterogeneity across studies for instruments employed, measurement timing and clinical characteristics. For harms, no differences between RFA and medical therapy in 30-day mortality, stroke, or three-month risk of AF were seen, with low strength of evidence. Evidence comparing cryoballoon ablation with medical therapy or with RFA was insufficient to draw conclusions regarding efficacy or safety, with the exception of low strength of evidence for greater freedom from protocol-defined failure following cryoballoon ablation versus medical therapy. To better understand the impact of catheter ablation on key outcomes (stroke, mortality, quality of life, and symptom improvement) compared to other treatment strategies, large methodologically sound studies are needed. Studies with sufficient sample sizes are needed to effectively determine whether catheter ablation versus other treatments will benefit certain patient subgroups more than others, and whether there are subgroups in which catheter ablation might best used as a first- versus second-line treatment.