# Description of Outcomes Measures, Devices, and Ongoing Trials, and Additional Results Tables

Table H1 Descriptions and Scoring Details for Health Related Quality of Life Measures used in Included Studies

HRQOL measure | Description | Scoring
Short-Form (SF-36) General measure | - 36-items, self-administered, constructed to survey health status and quality of life; - 8 health domains: limitations in physical activities because of health problems; limitations in social activities because of physical or emotional problems; limitations in usual role activities because of physical health problems; bodily pain; general mental health (psychological distress and well-being); limitations in usual role activities because of emotional problems; vitality (energy and fatigue); general health perceptions; - Summary Mental and Physical Component score are generated using a proprietary algorithm supplied by the instrument developers | - Likert-type scales (some with 5 or 6 points and others with 2 or 3 points); - Scores are transformed to a range of 0 (worst) to 100 (best)
European Quality of Life-5 Dimensions (EQ5D) General measure | - 25 items, self-administered; - 5 categories: anxiety/depression, mobility, pain, self-care, usual activity; - Contains an additional category relating to health state today; score on a 0 to 100 VAS scale (not part of the final score) | - Items ranked from 1 to 3 depending on level of disability; - Preferential weights are assigned to each health state level to obtain a score of 0 (death) to 1 (optimal health) (societal-based utility score)
Zung Self-Rating Depression Scale (SDS) General measure | - 20 items, self-administered; - questions assess psychological and somatic symptoms associated with depression | - All items are 1–4 Likert-type scale; - Scores are transformed to a range of 20 (best) to 80 (worst); - Most people with depression score between 50 and 69, while a score of 70 and above indicates severe depression
Zung Self-Rating Anxiety Scale (SAS) General measure | - 20 items, self-administered; - 4 groups of manifestations: cognitive, autonomic, motor and central nervous system symptoms | - All items are 1–4 Likert-type scale; - Scores are transformed to a range of 20 (best) to 80 (worst); - Most people with anxiety score between 45 and 59, while a score of 60 and above indicates severe or extreme anxiety
Atrial Fibrillation Quality of Life Questionnaire (AF-QOL) Disease-specific measure | - 18 items, self-administered, measures the health-related quality of life in patients with AF; - 3 domains: psychological (7 items), physical (8 items), and sexual activity (3 items). | - Scores standardized from 0 (worst) to 100 (best)
Kansas City Cardiomyopathy Questionnaire (KCCQ) Disease-specific measure | - 23 items, self-administered; - 5 categories: physical function, symptoms (frequency, severity and recent change), social function, self-efficacy and knowledge, and quality of life | - Scores are transformed to a range of 0 (worst) to 100 (best)
Minnesota Living with Heart Failure Questionnaire (MLHFQ) Disease-specific measure | - 21 items, self-administered, measures the effects of symptoms, functional limitations, and psychological distress on an individual’s quality of life; - questions assess the impact of frequent physical symptoms, the effects of heart failure on physical/social functions, and side effects of treatments, hospital stays, and costs of care | - All items are 0–5 Likert-type scale in which a lower score reflects better health status.
Symptom Checklist – Frequency and Severity Scales Disease-specific measure | - 16 items for both scales, self-administered; - measures the patient's perception of the frequency and severity of arrhythmia-related symptoms | Frequency Scale; - All items are 0–4 Likert-type scale; - Scores range from 0 (worst) to 64 (best); Severity Scale; - All items are 1–3 Likert-type scale; - Scores range from 0 (worst) to 48 (best)

Table H2 SF-36 domain scores from RCTs comparing RF ablation with medical therapy for the treatment of AF

SF-36 domains (mean ± SD)^*^ | AF Type | 1^st^/2^nd^ line therapy | Study | Followup | RF Ablation | Medical Therapy | p-value
Physical functioning | Paroxysmal | 1^st^ line | Wazni 2005^59^ | | n = 32 | n = 35
Physical functioning | Paroxysmal | 1^st^ line | Wazni 2005^59^ | Baseline | 71 ± 3 | 69 ± 2 | NR
Physical functioning | Paroxysmal | 1^st^ line | Wazni 2005^59^ | 6 months | 97 ± 3 | 75 ± 7.5 | 0.001
Physical functioning | Paroxysmal | 1^st^ line
Physical functioning | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | | n = 99 | n = 99
Physical functioning | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | Baseline | 69 ± 18 | 68 ± 21 | NS
Physical functioning | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | 48 months | 85 ± 12 | 82 ± 15 | NR
Physical functioning | Paroxysmal
Physical functioning | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | n = 26 | n = 24
Physical functioning | Persistent | 1^st^/2^nd^ line | Hunter 2014 | 6 months | 71% | 49.1% | p = 0.007
Physical functioning | Persistent
Physical functioning | Mixed population | 2^nd^ line | Forleo 2009^66^ | | n = 35 | n = 35
Physical functioning | Mixed population | 2^nd^ line | (Diabetes) | Baseline | NR | NR
Physical functioning | Mixed population | 2^nd^ line | (Diabetes) | Difference in mean change at 12 months between groups | NR | NR | 8.4^†^ <0.05
Role physical | Paroxysmal | 1^st^ line | Wazni 2005^59^ | | n = 32 | n = 35
Role physical | Paroxysmal | 1^st^ line | Wazni 2005^59^ | Baseline | 73 ± 5 | 51 ± 5 | NR
Role physical | Paroxysmal | 1^st^ line | Wazni 2005^59^ | 6 months | 71 ± 2 | 53 ± 3 | 0.047
Role physical | Paroxysmal | 1^st^ line
Role physical | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | | n = 99 | n = 99
Role physical | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | Baseline | 63 ± 19 | 61 ± 17 | NS
Role physical | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | 48 months | 82 ± 14 | 80 ± 15 | NR
Role physical | Paroxysmal
Role physical | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | n = 26 | n = 24
Role physical | Persistent | 1^st^/2^nd^ line | Hunter 2014 | 6 months | 67.5% | 42.4% | p = 0.004
Role physical | Persistent
Role physical | Mixed population | 2^nd^ line | Forleo 2009^66^ | | n = 35 | n = 35
Role physical | Mixed population | 2^nd^ line | (Diabetes) | Baseline | NR | NR
Role physical | Mixed population | 2^nd^ line | (Diabetes) | Difference in mean change at 12 months between groups | NR | NR | NS
Bodily pain | Paroxysmal | 1^st^ line | Wazni 2005^59^ | | n = 32 | n = 35
Bodily pain | Paroxysmal | 1^st^ line | Wazni 2005^59^ | Baseline | 71 ± 3 | 70 ± 3 | NR
Bodily pain | Paroxysmal | 1^st^ line | Wazni 2005^59^ | 6 months | 97 ± 1 | 90 ± 3 | 0.004
Bodily pain | Paroxysmal | 1^st^ line
Bodily pain | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | | n = 99 | n = 99
Bodily pain | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | Baseline | 68 ± 19 | 66 ± 24 | NS
Bodily pain | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | 48 months | 80 ± 17 | 77 ± 21 | NR
Bodily pain | Paroxysmal
Bodily pain | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | n = 26 | n = 24
Bodily pain | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | 78.8% | 57.1% | p = 0.005
Bodily pain | Persistent
Bodily pain | Mixed population | 2^nd^ line | Forleo 2009^66^ | | n = 35 | n = 35
Bodily pain | Mixed population | 2^nd^ line | (Diabetes) | Baseline | NR | NR
Bodily pain | Mixed population | 2^nd^ line | (Diabetes) | Difference in mean change at 12 months between groups | NR | NR | 5.9^†^ <0.05
General health | Paroxysmal | 1^st^ line | Wazni 2005^59^ | | n = 32 | n = 35
General health | Paroxysmal | 1^st^ line | Wazni 2005^59^ | Baseline | 57 ± 2 | 57 ± 2 | NR
General health | Paroxysmal | 1^st^ line | Wazni 2005^59^ | 6 months | NR^‡^ | 68 ± 2 | <0.001
General health | Paroxysmal | 1^st^ line
General health | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | | n = 99 | n = 99
General health | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | Baseline | 65 ± 17 | 67 ± 17 | NS
General health | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | 48 months | 79 ± 15 | 77 ± 16 | NR
General health | Paroxysmal
General health | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | n = 26 | n = 24
General health | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | NR | NR | NS
General health | Persistent
General health | Mixed population | 2^nd^ line | Forleo 2009^66^ | | n = 35 | n = 35
General health | Mixed population | 2^nd^ line | (Diabetes) | Baseline | NR | NR
General health | Mixed population | 2^nd^ line | (Diabetes) | Difference in mean change at 12 months between groups | NR | NR | 8.9^†^ <0.05
Vitality | Paroxysmal | 1^st^ line | Wazni 2005^59^ | | n = 32 | n = 35
Vitality | Paroxysmal | 1^st^ line | Wazni 2005^59^ | Baseline | 52 ± 4 | 51 ± 1 | NR
Vitality | Paroxysmal | 1^st^ line | Wazni 2005^59^ | 6 months | 65 ± 1 | 60 ± 2 | .21
Vitality | Paroxysmal | 1^st^ line
Vitality | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | | n = 99 | n = 99
Vitality | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | Baseline | 56 ± 22 | 55 ± 18 | NS
Vitality | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | 48 months | 71 ± 23 | 68 ± 21 | NR
Vitality | Paroxysmal
Vitality | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | n = 26 | n = 24
Vitality | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | 54.3% | 36.4% | p = 0.009
Vitality | Persistent
Vitality | Mixed population | 2^nd^ line | Forleo 2009^66^ | | n = 35 | n = 35
Vitality | Mixed population | 2^nd^ line | (Diabetes) | Baseline | NR | NR
Vitality | Mixed population | 2^nd^ line | (Diabetes) | Difference in mean change at 12 months between groups | NR | NR | NS
Social Functioning | Paroxysmal | 1^st^ line | Wazni 2005^59^ | | n = 32 | n = 35
Social Functioning | Paroxysmal | 1^st^ line | Wazni 2005^59^ | Baseline | 78 ± 3 | 76 ± 3 | NR
Social Functioning | Paroxysmal | 1^st^ line | Wazni 2005^59^ | 6 months | 93 ± 3 | 82 ± 2 | 0.004
Social Functioning | Paroxysmal | 1^st^ line
Social Functioning | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | | n = 99 | n = 99
Social Functioning | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | Baseline | 68 ± 22 | 66 ± 20 | NS
Social Functioning | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | 48 months | 87 ± 14 | 86 ± 14 | NR
Social Functioning | Paroxysmal
Social Functioning | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | n = 26 | n = 24
Social Functioning | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | NR | NR | NS
Social Functioning | Persistent
Social Functioning | Mixed population | 2^nd^ line | Forleo 2009^66^ | | n = 35 | n = 35
Social Functioning | Mixed population | 2^nd^ line | (Diabetes) | Baseline | NR | NR
Social Functioning | Mixed population | 2^nd^ line | (Diabetes) | Difference in mean change at 12 months between groups | NR | NR | 7.7^†^ <0.05
Role emotional | Paroxysmal | 1^st^ line | Wazni 2005^59^ | | n = 32 | n = 35
Role emotional | Paroxysmal | 1^st^ line | Wazni 2005^59^ | Baseline | 70 ± 1 | 70 ± 1 | NR
Role emotional | Paroxysmal | 1^st^ line | Wazni 2005^59^ | 6 months | 76 ± 1 | 75 ± 1 | .90
Role emotional | Paroxysmal | 1^st^ line
Role emotional | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | | n = 99 | n = 99
Role emotional | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | Baseline | 70 ± 24 | 70 ± 22 | NS
Role emotional | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | 48 months | 86 ± 18 | 84 ± 19 | NR
Role emotional | Paroxysmal
Role emotional | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | n = 26 | n = 24
Role emotional | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | NR | NR | NS
Role emotional | Persistent
Role emotional | Mixed population | 2^nd^ line | Forleo 2009^66^ | | n = 35 | n = 35
Role emotional | Mixed population | 2^nd^ line | (Diabetes) | Baseline | NR | NR
Role emotional | Mixed population | 2^nd^ line | (Diabetes) | Difference in mean change at 12 months between groups | NR | NR | 6.8† <0.05
Mental health | Paroxysmal | 1^st^ line | Wazni 2005^59^ | | n = 32 | n = 35
Mental health | Paroxysmal | 1^st^ line | Wazni 2005^59^ | Baseline | 65 ± 4 | 64 ± 2 | NR
Mental health | Paroxysmal | 1^st^ line | Wazni 2005^59^ | 6 months | 65 ± 2 | 68 ± 3 | 0.62
Mental health | Paroxysmal | 1^st^ line
Mental health | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | | n = 99 | n = 99
Mental health | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | Baseline | 66 ± 21 | 67 ± 19 | NS
Mental health | Paroxysmal | 2^nd^ line | Pappone 2011^58^ | 48 months | 81 ± 17 | 78 ± 17 | NR
Mental health | Paroxysmal
Mental health | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | n = 26 | n = 24
Mental health | Persistent | 1^st^/2^nd^ line | Hunter 2014 | | NR | NR | NS
Mental health | Persistent
Mental health | Mixed population | 2^nd^ line | Forleo 2009^66^ | | n = 35 | n = 35
Mental health | Mixed population | 2^nd^ line | (Diabetes) | Baseline | NR | NR
Mental health | Mixed population | 2^nd^ line | (Diabetes) | Difference in mean change at 12 months between groups | NR | NR | NS

AF = atrial fibrillation; NR = not reported; NS = not significant; RF = radiofrequency; SD = standard deviation; SF-36 = Short Form-36 Questionnaire.

* A higher score reflects better health status.

† Difference in mean change of QoL scores between groups. Favored RF Ablation.

‡ Authors report this value as 9 ± 1; however, this appears to be a typo in the article and the correct value cannot be ascertained. The authors report that the improvement in quality of life of patients in the ablation group was significantly better than the improvement in quality of life in the medical group.

Table H3 SF-36 domain scores from comparative observational studies comparing RF ablation with medical therapy for the treatment of AF

SF-36 domains (mean ± SD)^*^ | AF Type^†^ | Study^‡^ | Followup | RF Ablation | Medical Therapy | p-value
Physical functioning | Persistent | Blandino 2013^71^ | | n = 153 | n = 259
Physical functioning | Persistent | Blandino 2013^71^ | Baseline | 44.2 ± 25.4 | 58.7 ± 25.2 | <0.001
Physical functioning | Persistent | Blandino 2013^71^ | Change from baseline (mean 60 months) | 36.4 ± 33.4 | 9.9 ± 35.3 | <0.001
Physical functioning | Persistent
Physical functioning | Paroxysmal | Yu 2012^70^ | | n = 97 | n = 102
Physical functioning | Paroxysmal | Yu 2012^70^ | Baseline | 83.17 ± 12.98 | 81.29 ± 22.44 | NR
Physical functioning | Paroxysmal | Yu 2012^70^ | 12 months | 85.26 ± 11.40 | 83.10 ± 16.12 | NR
Role physical | Persistent | Blandino 2013^71^ | | n = 153 | n = 259
Role physical | Persistent | Blandino 2013^71^ | Baseline | 25.5 ± 37.6 | 59.0 ± 42.2 | <0.001
Role physical | Persistent | Blandino 2013^71^ | Change from baseline (mean 60 months) | 61.2 ± 53.4 | 10.5 ± 53.6 | <0.001
Role physical | Persistent
Role physical | Paroxysmal | Yu 2012^70^ | | n = 97 | n = 102
Role physical | Paroxysmal | Yu 2012^70^ | Baseline | 54.12 ± 16.72 | 52.70 ± 8.06 | NR
Role physical | Paroxysmal | Yu 2012^70^ | 12 months | 63.45 ± 10.10 | 57.48 ± 8.14 | NR
Bodily pain | Persistent | Blandino 2013^71^ | | n = 153 | n = 259
Bodily pain | Persistent | Blandino 2013^71^ | Baseline | 86.9 ± 18.8 | 99.3 ± 5.1 | <0.001
Bodily pain | Persistent | Blandino 2013^71^ | Change from baseline (mean 60 months) | 0.8 ± 23.8 | −1.5 ± 10.3 | 0.21
Bodily pain | Persistent
Bodily pain | Paroxysmal | Yu 2012^70^ | | n = 97 | n = 102
Bodily pain | Paroxysmal | Yu 2012^70^ | Baseline | 92.91 ± 14.20 | 90.06 ± 14.89 | NR
Bodily pain | Paroxysmal | Yu 2012^70^ | 12 months | 95.11 ± 11.13 | 91.17 ± 10.41 | NR
General health | Persistent | Blandino 2013^71^ | | n = 153 | n = 259
General health | Persistent | Blandino 2013^71^ | Baseline | 33.6 ± 16.8 | 57.2 ± 18.1 | <0.001
General health | Persistent | Blandino 2013^71^ | Change from baseline (mean 60 months) | 44.2 ± 26.0 | 6.1 ± 25.3 | <0.001
General health | Persistent
General health | Paroxysmal | Yu 2012^70^ | | n = 97 | n = 102
General health | Paroxysmal | Yu 2012^70^ | Baseline | 51.65 ± 12.78 | 48.06 ± 13.11 | NR
General health | Paroxysmal | Yu 2012^70^ | 12 months | 54.86 ± 9.75 | 51.58 ± 13.53 | NR
Vitality | Persistent | Blandino 2013^71^ | | n = 153 | n = 259
Vitality | Persistent | Blandino 2013^71^ | Baseline | 38.6 ± 18.1 | 52.0 ± 15.9 | <0.001
Vitality | Persistent | Blandino 2013^71^ | Change from baseline (mean 60 months) | 37.0 ± 29.8 | 4.7 ± 23.1 | <0.001
Vitality | Persistent
Vitality | Paroxysmal | Yu 2012^70^ | | n = 97 | n = 102
Vitality | Paroxysmal | Yu 2012^70^ | Baseline | 66.08 ± 11.57 | 59.42 ± 14.69 | NR
Vitality | Paroxysmal | Yu 2012^70^ | 12 months | 73.56 ± 9.74 | 64.76 ± 10.54 | NR
Social Functioning | Persistent | Blandino 2013^71^ | | n = 153 | n = 259
Social Functioning | Persistent | Blandino 2013^71^ | Baseline | 42.4 ± 19.4 | 79.8 ± 20.3 | <0.001
Social Functioning | Persistent | Blandino 2013^71^ | Change from baseline (mean 60 months) | 38.1 ± 35.1 | 3.2 ± 22.0 | <0.001
Social Functioning | Persistent
Social Functioning | Paroxysmal | Yu 2012^70^ | | n = 97 | n = 102
Social Functioning | Paroxysmal | Yu 2012^70^ | Baseline | 66.88 ± 15.84 | 59.47 ± 15.64 | NR
Social Functioning | Paroxysmal | Yu 2012^70^ | 12 months | 69.90 ± 16.22 | 58.00 ± 12.16 | NR
Role emotional | Persistent | Blandino 2013^71^ | | n = 153 | n = 259
Role emotional | Persistent | Blandino 2013^71^ | Baseline | 31.2 ± 41.2 | 81.3 ± 35.2 | <0.001
Role emotional | Persistent | Blandino 2013^71^ | Change from baseline (mean 60 months) | 53.6 ± 49.5 | −0.7 ± 36.6 | <0.001
Role emotional | Persistent
Role emotional | Paroxysmal | Yu 2012^70^ | | n = 97 | n = 102
Role emotional | Paroxysmal | Yu 2012^70^ | Baseline | 77.32 ± 18.05 | 69.40 ± 17.20 | NR
Role emotional | Paroxysmal | Yu 2012^70^ | 12 months | 83.96 ± 10.45 | 73.02 ± 11.29 | NR
Mental health | Persistent | Blandino 2013^71^ | | n = 153 | n = 259
Mental health | Persistent | Blandino 2013^71^ | Baseline | 45.2 ± 21.2 | 61.8 ± 14.2 | <0.001
Mental health | Persistent | Blandino 2013^71^ | Change from baseline (mean 60 months) | 36.7 ± 30.9 | 3.7 ± 19.5 | <0.001
Mental health | Persistent
Mental health | Paroxysmal | Yu 2012^70^ | | n = 97 | n = 102
Mental health | Paroxysmal | Yu 2012^70^ | Baseline | 73.15 ± 13.01 | 67.83 ± 15.89 | NR
Mental health | Paroxysmal | Yu 2012^70^ | 12 months | 80.21 ± 11.26 | 69.78 ± 12.77 | NR

AF = atrial fibrillation; NR = not reported; RF = radiofrequency.

* A higher score reflects better health status.

† All treatments were a second-line therapy for AF.

‡ Blandino et al. 2013 is a Medicare population (age ≥ 75 years). All other studies represent the general adult population.

Table H4 Adverse events for case series evaluating catheter ablation for the treatment of AF

Adverse Event | Number of Studies (N) | Number of Patients | Energy Type | Percent Patients
MAJOR EVENTS (< 30 DAYS)
Mortality (all cause) | 5^84–88^ | N = 1000–5947 | RF | 0%–0.4%
| 2^89, 90^ | 1190–93,801 procedures | RF | 0%–0.4% procedures
| 4^91–94^ | N = 1273–15,423 | Mixed | 0.1%–0.8%
Stroke (any type)^*^ | 6^84, 85, 87, 88, 95, 96^ | N = 1000–7217 | RF | 0.08%–0.71%
| 1^90^ | 1190 procedures | RF | 0.8% procedures
| 2^93, 94^ | 4156–6207 | Mixed | 0.2%–0.6%
Stroke/TIA | 2^89, 97^ | 1506–93,801 procedures | RF | 0.4%–1.0% procedures
| 2^91, 92^ | N = 1273–15,423 | Mixed | 0.7%–0.8%
Transient ischemic attack | 6^84–88, 95^ | N = 1000–5947 | RF | 0.1%–0.6%
| 1^90^ | 1190 procedures | RF | 0.3% procedures
| 1^93^ | N = 4156 | Mixed | 0.07%
Other embolic events | 2^84, 88^ | N = 1294–5947 | RF | 0.08%–0.7%
Myocardial infarction | 1^88^ | N = 5947 | RF | 0.3%
| 1^89^ | 93,801 procedures | RF | 0.37% procedures
| 1^92^ | N = 15,423 | Mixed | 0.31%
Bleeding (major)/ hemorrhage/ transfusion | 1^88^ | N = 5947 | RF | 3.7%
| 3^89, 90, 97^ | 1190–93,801 procedures | RF | 0.07%–4.0% procedures
| 1^94^ | N = 6207 | Mixed | 2.1%
Other major events | 1^91^ | N = 1273 | Mixed | 0.8%
ABLATION-RELATED EVENTS^†^
Cardiac tamponade^*^ | 4^85–87, 96^ | N = 1000–7217 | RF | 0.6%–1.3%
| 1^90^ | 1190 procedures | RF | 1.1% procedures
| 3^91, 93, 94^ | N = 1273–6207 | Mixed | 2.5%–6.7%
| 1^98^ | 34,943 procedures | Mixed | 0.8% procedures
Cardiac tamponade or pericardial effusion | 1^97^ | 1506 procedures | RF | 0.8% procedures
Pericardial effusion or cardiac tamponade requiring pericardiocentesis | 1^88^ | N = 5947 | RF | 0.42%
Pericardial effusion | 4^84, 85, 88, 99^ | N = 1011–5947 | RF | 0.1%–6.0%
Pericardial effusion or cardiac tamponade requiring pericardiocentesis | 1^88^ | N = 5947 | RF | 0.4%
| 1^97^ | 1506 procedures | RF | 0.8% procedures
| 1^92^ | N = 15,423 | Mixed | 1.7%
Pericardial complications | 1^89^ | 93,801 procedures | RF | 1.5% procedures
Pulmonary vein stenosis | 4^84, 85, 87, 99^ | N = 1000–1380 | RF | 0%–0.4%
| 2^90, 97^ | 1190–1506 procedures | RF | 0.08%–0.4% procedures
| 1^91^ | N = 1273 | Mixed | 0.2%
Hematoma | 2^91, 94^ | N = 1273–6207 | Mixed | 2.1%–3.7%
Atrioesophageal fistula | 3^84, 87, 99^ | N = 1000–1380 | RF | 0%–0.2%
| 2^90, 97^ | 1190–1506 procedures | RF | 0%–0.07% procedures
Arteriovenous fistula | 2^85, 87^ | N = 1000–1011 | RF | 0.1%–0.3%
| 2^90, 97^ | 1190–1506 procedures | RF | 0.2%–0.7% procedures
Atrioventricular fistula | 1^86^ | N = 4212 | RF | 0.2%
Persistent postoperative fistula (not otherwise specified) | 1^88^ | N = 5947 | RF | 0.1%
Phrenic nerve paralysis | 5^84, 85, 88, 99, 100^ | N = 1011–5947 | RF | 0%–0.5%
| 1^90^ | 1190 procedures | RF | 0% procedures
Phrenic nerve injury | 1^97^ | 1506 procedures | RF | 0.13% procedures
Heart block | 1^85^ | N = 1011 | RF | 0.1%
| 1^90^ | 1190 procedures | RF | 0.08% procedures
Perforation at transseptal puncture | 1^85^ | N = 1011 | RF | 0.1%
Esophageal perforation | 1^86^ | N = 4212 | RF | 0.05%
Endocarditis | 1^87^ | N = 1000 | RF | 0.2%
Pneumothorax | 2^85, 88^ | N = 1011–5947 | RF | 0.1%–0.3%
| 1^89^ | 93,801 procedures | RF | 0.4% procedures
Hemothorax | 1^85^ | N = 1011 | RF | 0.1%
| 1^90^ | 1190 procedures | RF | 0.2% procedures
Pneumothorax or Hemothorax | 1^93^ | N = 4156 | Mixed | 0.1%
Mitral valve injury | 1^90^ | 1190 procedures | RF | 0.1% procedures
Iatrogenic cardiac complications | 1^89^ | 93,801 procedures | RF | 1.2% procedures
Other iatrogenic respiratory complications | 1^89^ | 93,801 procedures | RF | 0.2% procedures
PERIPHERAL VASCULAR COMPLICATIONS
Hematoma at insertion site | 1^99^ | N =1380 | RF | 0.4%
| 1^97^ | 1506 procedures | RF | 0.2% procedures
Vascular injury due to access | 1^84^ | N = 1294 | RF | 2.4%
| 1^91^ | N = 1273 | Mixed | 0.1%
Vascular complication requiring surgical repair | 1^89^ | 93,801 procedures | RF | 1.0% procedures
| 2^92, 93^ | N = 4156–15,423 | Mixed | 0.5%–2.6%
Retroperitoneal hematoma | 1^87^ | N = 1000 | RF | 0.1%
Pseudoaneurysm | 2^85, 87^ | N = 1000–1011 | RF | 0.6%–1.0%
| 2^90, 97^ | 1190–1506 procedures | RF | 0.6% procedures
OTHER ADVERSE EVENTS
Postoperative infectious complications | 1^89^ | 93,801 procedures | RF | 0.4% procedures
Deep vein thrombosis | 2^84, 87^ | N = 1000–1294 | RF | 0.08%–0.1%
| 1^97^ | 1506 procedures | RF | 0.07% procedures
Respiratory compromise/failure | 2^89, 90^ | 1190–93,801 procedures | RF | 0.4%–0.8% procedures
Aspiration with or without pneumonia | 1^87^ | N = 1000 | RF | 0.2%
Pulmonary hypertension | 1^99^ | N = 1380 | RF | 1.4%
Requiring open heart surgery | 1^89^ | 93,801 procedures | RF | 0.3% procedures
Hospitalization (all-cause) | 1^93^ | N = 4156 | Mixed | 9.4%
Anaphylaxis | 1^97^ | 1506 procedures | RF | 0.13% procedures
Radiation burn | 1^97^ | 1506 procedures | RF | 0.07% procedures
Air embolism with transient ST changes | 1^97^ | 1506 procedures | RF | 0.07% procedures
Fluid overload prolonging hospitalization | 1^97^ | 1506 procedures | RF | 0.13% procedures

Mixed: radiofrequency ablation or cryoballoon ablation (not reported separately); RF: radiofrequency ablation only.

* One of the included studies is a meta-analysis of case-series of AF ablation (D’Ascenzo 2013).

† Denominator is the number of patients who underwent the procedure.

Table H5 Table of FDA-Approved Catheter Ablation Devices

Device (PMA #) | Date Approved | Manufacturer
Atrial Fibrillation
NAVISTAR® THERMOCOOL® and EZ Steer THERMOCOOL® Nav Irrigated Deflectable Diagnostic/Ablation Catheter for Treatment of Paroxysmal Atrial Fibrillation (P030031S011) | 2009 | Biosense Webster, Inc.
Arctic Front® Cardiac CryoAblation Catheter (P100010) Includes models 2AF232 and 2AF282; Freezor® MAX Cardiac CryoAblation Catheter (Models 239F3 and 239F5); CryoConsole (Model 106A2); Manual Retraction Kit (Model 20MRK) | 2010 | Medtronic Cryocath, LP
Arctic Front Advance™ Cardiac Cryoballoon | 2012 | Medtronic Cryocath, LP
Atrial Flutter
NaviStar DS and Celsius DS Diagnostic/Ablation Catheters, Stockert 70 RF Generator and accessories (P010068) | 2002 | Biosense Webster, Inc.
Blazer II XP™ Cardiac Ablation Catheter, EPT-1000 XP Cardiac Ablation Controller and Accessories (P020025) | 2003 | Boston Scientific Corporation, Electrophysiology Division
NAVISTAR™ and CELSIUS™ THERMOCOOL® Irrigated Deflectable Diagnostic/Ablation Catheter (P030031) | 2004 | Biosense Webster, Inc.
IBI Therapy™ Dual 8™ Ablation Catheter and IBI 1500T6 (USA) Cardiac Ablation Generator (P040042) | 2005 | Irvine Biomedical, Inc.
IBI Therapy™ Cool Path™ Ablation Catheter and IBI 1500T9 RF Generator (P060019) | 2007 | Irvine Biomedical, Inc.
CryoCor Cryoablation System (CryoBlator Catheters & Model 2020 Console) (P050024) | 2007 | CryoCor, Inc.
Helios II Ablation Catheter (P050029) | 2008 | Stereotaxis, Inc.
Therapy Cool Path Duo™ Ablation Catheter, Safire BLU Duo™ Ablation Catheter, and IBI1500T9-CP V1.6 Cardiac Ablation Generator (P110016) | 2012 | Irvine Biomedical, Inc.
Other indications
Blazer II™ Cardiac Ablation Catheter, EPT-1000 Cardiac Ablation Controller and Accessories (P920047) | 1994 | Boston Scientific Corporation, Electrophysiology Division
Atakr™ Radiofrequency Catheter Ablation (RFCA) System (P930029) | 1995 | Medtronic, Inc.
Webster Diagnostic/Ablation Deflectable Tip Catheter (P950005) | 1997 | Cordis Corporation
Chilli Cooled RF Ablation System (P980003) Includes Chilli Cooled Ablation Catheter, Standard Curve, and Chilli Cooled Ablation Catheter, Large Curve | 1999 | Boston Scientific Corporation
Livewire TC® Steerable Electrophysiology Catheter and Accessory Cables (P960016) | 1999 | Daig Corporation
Stinger™ Ablation Catheter and TempLink™ Extension Cable (P000020) | 2000 | C.R. Bard, Inc., Bard Electrophysiology Division
NAVISTAR™ Diagnostic/Ablation Deflectable Tip Catheter (P990025) | 2000 | Biosense Webster, Inc.
7F Freezor® Cardiac Cryoablation Catheter and CCT.2 CryoConsole System (P020045) | 2003 | Medtronic Cryocath, LP
IBI Therapy™ Cardiac Ablation System (P040014) | 2005 | Irvine Biomedical
NAVISTAR™ THERMOCOOL® Deflectable Diagnostic/Ablation Catheter (P040036) | 2006 | Biosense Webster, Inc.
FIRMap Catheter™ (K021232) | 2013 | Topera, Inc.

AF: atrial fibrillation; FDA: Food and Drug Administration; PMA: premarket approval number;

Table H6 Catheter details, mapping information and ablation approaches used in included studies

Study | Catheter Used | Mapping | Ablation Approach
RFA vs. Medical Therapy
Randomized Controlled Trials
Cosedis Nielsen, 2012 | 3.5-mm catheter with an irrigated tip (NaviStar ThermoCool, Biosense Webster) or an 8-mm solid-tip catheter (for 15 procedures; NaviStar DS, Biosense Webster). | - Carto^*^ | - Circumferential PVI (%NR); - Roof of the atrium (%NR); - Cavotricuspid and mitral isthmuses (optional) (%NR)
Forleo, 2009 | 3.5 mm cooled-tip catheter | - NavX^‡^ with Carto* | - Circumferential PVI 100% (35/35); - Bidirectional cavotricuspid isthmus block 100% (35/35); - Mitral isthmus 23% (8/35); - Roofline ablation 9% (3/35)
Hunter, 2014 | Irrigated-tip catheter | - Either Carto^*^ or NavX^‡^ | - Circumferential PVI (%NR); - PVI + lines (%NR); - Cavotricuspid lines (%NR)
Jais, 2008 | Either a 3.5- or 5-mm irrigated tip (Thermocool, Biosense Webster; n95) or a 4-mm nonirrigated tip (n13) | - Lasso Circular mapping catheter^§^ | - Left PVI 100% (53/53); - Right PVI 100% (53/53); - Right inferior vein isolation 100% (53/53); - Cavotricuspid isthmus 64.2% (34/53); - Roof of the left atrium 17% (9/53); - Mitral isthmus 30.2% (16/53); - Foci from nonvenous structures 22.6% (12/53)
Jones, 2013 | 3.5-mm irrigated-tip catheter (ThermoCool, Biosense Webster, Diamond Bar, California) | - NavX^‡^ mapping system with an AFoucsII catheter | - PVI (%NR); - Linear ablation to the left atrial roof and mitral isthmus (%NR); - Left atrial CFAE (%NR)
MacDonald, 2011 | Irrigated tip ablation catheter (ThermoCool, Biosense Webster) | - Pulmonary venous angiography and three-dimensional reconstruction of the left atrium using NavX^‡^ mapping system; - Pulmonary vein recordings were performed with a duodecapolar variable-diameter circular mapping catheter (Lasso^§^ or Inquiry Optima^‡‡^) | - PVI with an additional adjoining roof line and further ablation at sites of CFAEs 100% (21/21); - Additional atrial flutter ablation 9.5% (2/21)
Mont, 2013 | Cooled-tip catheter | - Carto^*^ or NavX^‡^ | - PVI 100% (93/93); - PVI + cavotricuspid isthmus 2% (2/93); - PVI + mitral isthmus line 3.1% (3/93); - PVI+ roof line 23.4% (23/93); - PVI + CFAE 8.1% (8/93)
Morillo, 2014 | Selection of ablation catheter, power and irrigation settings, and use of navigation systems were left to the discretion of the investigator | - Nonfluroscopic mapping systems were used in 86% of patients (no other details) | - Circumferential PVI 98.5% (65/66); - PVI + cavotricuspid isthmus (%NR); - PVI + CFAE (%NR); - PVI+ roof line (%NR)
Oral, 2006 | Temperature-controlled, quadripolar, deflectable catheter with an 8-mm tip (Navistar, Biosense Webster) | - Carto^*^ | - PVI: 100% (77/77); - PVI + cavotricuspid isthmus: 71% (55/77)
Pappone, 2006; 2011 | Either an 8-mm standard catheter (Navi-Star, Biosense-Webster or Livewire TC, St. Jude Medical, St. Paul, Minnesota) or an irrigated tip catheter (3.5-mm Cool-Path, St. Jude Medical or Thermo-Cool Navi-Star, Biosense-Webster) | - Either Carto^*^ or NavX^‡^ | - Circumferential PVI 100% (99/99); - PVI + cavotricuspid isthmus 100% (99/99)
Stabile, 2006 | 8 mm tip catheter | - Carto^*^ | - PVI + mitral isthmus, cavo-tricuspid isthmus, and circumferential PV ablation 100% (68/68), of these patients 13 patients had already undergone cavo-tricuspid ablations, only 55 of those procedures were completed during these trials
Wazni, 2005 | 8-mm tip ablation catheter (Biosense Webster, Baldwin Park, Calif, and EP Technologies, Sunnyvale, Calif ) | - Multipolar mapping catheter (no other details) | - PVI of all 4 veins 100% (33/33)
Wilber, 2010; Reynolds 2010 | NaviStar ThermoCool Irrigated Tip Catheter; (Biosense Webster, Diamond Bar, California) | - Carto^*^ | - PVI 100% (103/103); - PVI + cavotricuspid isthmus 35.9% (37/103); - PVI + superior vena cava 16.5% (17/103); - PVI + other left/ right atrial foci 16.5% (17/103); - PVI + at least 1 left atrial linear lesion (including mitral isthmus and roof lines) 22.3% (23/103)
Comparative Observational Studies
Blandino, 2013 | 3.5-mm irrigated tip ablation catheter (Navistar, Biosense Webster, Diamond Bar, CA, USA) | - Carto^*^ | - PVI + cavotricuspid isthmus100% (153/153); - Linear lesions interconnecting the upper PV ostia (roof line) and the left inferior PV with the mitral annulus (left isthmus line) 60% (92/153); only performed in cases of AF persistence despite PVI
Lan, 2009 | 8-mm tip catheter and/or the cooled 4-mm tip | - NR | - CPVA 50% (60/120); - SPVI 50% (60/120)
Reynolds, 2012 | NR | - NR | - PVI + superior vena cava 100% (85/85)
Rossillo, 2008 | 8mm tip catheter (Biosense-Webster) | - Mapping was carried out (no other details) | - PVI + superior vena cava 100% (85/85)
Sang, 2013 | 3.5-mm cool saline-irrigated ablation catheter (Navi-Star Thermo-Cool; Biosense-Webster Inc., Diamond Bar, CA) | - Carto^*^, sometimes PV isolation was confirmed with a Lasso circular mapping catheter | - Modified Brockenbrough technique; Circumferential isolation of the right pulmonary vein (PV) antrum (PVA) was performed first, followed by isolation of the left PVA %NR (n’s NR)
Sonne, 2009 | NR | - NR | - Pulmonary vein antrum isolation 100% (146/146)
Yu, 2012 | Navigation catheter | - Carto^*^ | - Circumferential PVI 100% (97/97)
Cryoballoon Ablation vs. Medical
Randomized Controlled Trials
Packer, 2013; Andrade, 2014 | Cryo: 23- or 28-mm (Medtronic, Inc.) Arctic Front cryoablation balloon catheter | Cryo:; - Pacing and a circular mapping catheter used (no other details) | - PVI of the four major PV’s 97.6% (159/163); - PVI achieved with the balloon catheter alone in 83% (135/163); - Additional catheter based focal cryoablation in one or more PVs for 16.6% (27/163); - Left common PV isolation 100% (21/21); - Right middle PVs 76.9% (10/13); - Cavotricuspid isthmus ablation with bidirectional block achieved in 97% (64/66)
Cryoballoon Ablation vs. RFA
Randomized Controlled Trials
Herrera Siklody, 2012 | RFA:; - Open irrigated tip catheter (ThermoCool, Biosense Webster, Diamond Bar, CA, USA); Cryoballoon:; - ArcticFront balloon (CryoCath, Medtronic, Minneapolis, MN USA) 28-mm balloon, 7 with a 23-mm balloon, and 2 using both sizes; - Touch up with 10-mm cryoablation catheter (Freezor MAX, CryoCath, Medtronic) | RFA:; - NavX^‡^; Cryoballoon:; - Circular mapping catheter^**^ | - Circumferential PVI of both ipsilateral veins with no further ablation beyond PVI allowed during the index procedure; - Electrical isolation was completed with focal applications 33% (10/30) in the cryoballoon group
Perez-Castellano, 2014 | RFA:; - 3.5-mm open-irrigated tip ablation catheter (Navistar ThermoCool, Biosense Webster); Cryoballoon:; - Arctic Front cryoablation balloon catheter (23 or 28 mm) | RFA:; - Carto^†^; - Selective PV angiograms were obtained through a 6-F angled pigtail catheter (Supertorque Plus)^††^; Cryoballoon:; - Lasso circular decapolar catheter^§^ | - PVI (100%); - Right inferior PV (1% each group); - Bidirectional block (83% cryo, 100% RFA); - Cavotricuspid isthmus ablation (4% cryo, 5% RFA)
Comparative Observational Studies
Chierchia, 2010 | RFA:; - Open irrigated cool tip 3.5 mm catheter (Navistar, Biosense Webster, Inc.); Cryoballoon:; - 28 mm double-walled cryoballoon (Arctic Front, Cryocath, Medtronic) | RFA:; - Carto^*^; Cryoballoon:; - Lasso circular mapping catheter^§^ | - Circumferential PVI with no additional lines 100%; - No touch-ups performed
Knecht, 2014 | RFA:; - 3.5 mm open irrigated-tip catheter; Cryoballoon:; - Arctic Front, Medtronic, Minneapolis, USA, 23-mm or other size | RFA:; - Carto3 or CartyXP systems (69%); - NavX system^‡^ (31%); Cryoballoon:; - Lasso2515 20-pole circumferential mapping catheter^§^ | - Acute PVI (100%); - Some cryoballoon patients required RFA to complete PVI (28.2%; 20/71) (authors report propensity score matched subgroup analysis in those patients who received cryoballoon only (n = 51) vs. RFA (n = 51))
Kojodjojo, 2010 | RFA:; - 4mm cooled tipped catheter (Thermocool, Biosense Webster, USA); - OR 8 mm tipped radiofrequency catheter for cavotricuspid ablation (IBI, St Jude Medical, USA) (60W, 608C); Cryoballoon:; - 28 mm cryoablation balloon (Arctic Front, Medtronic, USA); - Any residual LA-PV connections were treated by focal cryoablation (Freezor Max, Medtronic, USA) | RFA:; - Either fluoroscopy or Carto^*^; Cryoballoon:; - Inquiry Optima curvilinear mapping catheter^‡‡^ or Lasso^§^ | - PVI alone (15% RFA, 40% cryo); - PVI + Ostial focal cryoablaiton (60% cryo); - PVI + Cavotricuspid isthmus ablation with RFA catheter (11% RFA, 23% cryo)
Mandell, 2013 | RFA: NR Cryoballoon:; - Arctic Front Cardiac CryoAblation balloon catheter (Medtronic, Inc) | Imaging was performed in all patients using:; - Intracardiac echocardiography (to assist with the transeptal punctures and monitor for pericardial effusion); - single-plane fixed fluoroscopy; - NavX^‡^ | RFA:; - PVI only 79% (49/62); - PVI + cavotricuspid isthmus for atrial flutter 9.7% (6/62); - PVI + supraventricular tachycardia 1.6% (1/62); - PVI + superior vena cava 3.2% (2/62); - PVI + lines 1.6% (1/62); - PVI + cavotricuspid isthmus for atrial flutter + lines 1.6% (1/62); - CFE only 1.6% (1/62); - PVI + CFE 1.6% (1/62); Cryo:; - PVI only 75.8% (47/62); - PVI + cavotricuspid isthmus for atrial flutter 21% (13/62); - PVI + lines 3% (2/62); - Touch-up ablation with RFA 11% (7/62))
Mugnai, 2014 | RFA:; - Open irrigated cool tip 3.5-mm catheter (NaviStar ThermoCool; Biosense Webster Inc.); Cryoballoon:; - A first-generation 28-mm double-walled CB (Arctic Front; Cryocath) | RFA:; - Lasso circumferential mapping catheter^§^; - And Carto^*^; Cryoballoon:; - Lasso circular mapping catheter^§^ | - PVI (100%); - Cryo: Focal touch-up with either a focal-tip cryocatheter (Freezor Max; CryoCath Technologies Inc., Montreal, Quebec, Canada) or an irrigated-tip RF catheter (NaviStar ThermoCool; Biosense Webster Inc.) (3.7%, 5/136)
Schmidt, 2014 | RFA:; - RF Catheter; Cryoballoon:; - Arctic Front, Medtronic, Minneapolis, MN, USA; 23-mm or 28-mm balloon | RFA:; - Fluoroscopy; - OR Carto^*^ with or without integration of preprocedural imaging; - OR intracardiac echocardiography-guided mapping using a 10-Fr 64 element phased-array ultrasound imaging catheter (AcuNav^§§^); Cryoballoon:; - Conventional mapping (no further details) | - PVI (100%); - Cryo: Additional touch-up freezes with a conventional cryocatheter (Freezor MAX, CryoCath, Medtronic) or an RF catheter could be performed if deemed necessary: touchup focal cryoablation was reported in 10.6% of patients

CB: cryoballoon; CFE: continuous fractionated electrical activity; FU: Followup; NR: not reported; PVI: pulmonary venous isolation; RFA: Radiofrequency Ablation; SVC: superior vena cava; SVT: supraventricular tachycardia

* CARTO (Biosense Webster, Diamond Bar, CA, USA)

† (Biosense Webster, Tirat-Hacarmel, Israel)

‡ Ensite NavX (Endocaridal Solutions, St. Jude Medical, St. Paul, MN, USA)

§ Lasso Catheter (Biosense Webster, Inc, Diamond Bar, Calif)

** Circular mapping catheter (Optima, St. Jude Medical)

†† Supertorque Plus (Cordis Corp, Miami, FL)

‡‡ Inquiry Optima (St Jude Medical)

§§ AcuNav (Siemens Medical Solution, Malvern, PA, USA)

Table H7 Study definitions of AF Recurrence and study reported techniques for monitoring recurrences

Study | Study Definition of Recurrence | Recurrence Monitoring Technique
RFA vs. Medical Therapy
Randomized Controlled Trials
Cosedis Nielsen, 2012^54^ | Any AF (not defined further) or symptomatic AF (not defined further) | 7-day Holter-monitor recording
Forleo, 2009^66^ | Any ECG confirmed episode of AF or atypical atrial flutter lasting 30 seconds | All patients were instructed to regularly assess their pulse and to confirm on electrocardiogram (ECG Holter monitor) any suspected recurrence of arrhythmia.
Hunter, 2014^61^ | Documented AF/atrial tachycardia lasting ≥30 seconds | 12-lead ECG, and 48-hour ambulatory ECG monitoring at baseline and FU visits
Jais, 2008^55^ | AF lasting ≥ 3 minutes and documented by ECG or reported by the patients as AF (even in the absence of ECG confirmation) | 12-lead ECG, and 24-hour ambulatory Holter recording at baseline and FU visits
Jones, 2013^65^ | Atrial arrhythmia (assessed by ECG) lasting > 30 seconds | ECG rhythm documentation, plus 48-h ambulatory monitoring
MacDonald, 2011^62^ | Maintenance of sinus rhythm (not defined further) | 12-lead ECG; 24 h ambulatory ECG monitoring at baseline and final study visit
Mont, 2013; Wynn 2014^63, 101^ | AF or flutter lasting >24 hours or requiring cardioversion OR AF or flutter lasting ≥30 seconds | 12-lead ECG. A 24-h Holter monitor at followup
Morillo, 2014^56^ | Symptomatic or asymptomatic atrial tachyarrhythmia (AF, atrial flutter, atrial tachycardia) lasting > 30 seconds OR Symptomatic atrial tachyarrhythmia lasting > 30 seconds OR Symptomatic AF lasting > 30 seconds | Detected by either scheduled or unscheduled electrocardiogram, Holter, transtelephonic monitor, or rhythm strip.
Oral, 2006^64^ | AF or atrial flutter >3 seconds, documented by an event monitor (LifeWatch) | Cardiac rhythm was assessed with daily telephonic transmissions
Pappone, 2006; 2011^57, 58^ | Atrial tachyarrhythmias (including both AF and atrial tachycardia) | 12-lead ECG, 48-h Holter monitoring
Stabile, 2006^67^ | At least one occurrence of atrial arrhythmia (flutter or fibrillation) lasting >30 seconds | Multiple ECG and Holter monitoring, and, daily transtelephonic recording of ECGs
Wazni, 2005^59^ | Symptomatic or asymptomatic AF only lasting > 15 seconds during Holter or event monitoring | Patients were asked to record when they experienced symptoms and 2 to 3 times daily, even if they were asymptomatic. Additional event recorder monitoring at followup. Patients also monitored with a 24-hour Holter recording at followup. In addition, patients were called by telephone on a monthly basis.
Wilber, 2010; Reynolds 2010^60, 102^ | Symptomatic or asymptomatic atrial arrhythmia (AF, atrial tachycardia, or atrial flutter) OR Symptomatic atrial arrhythmia | Holter monitoring at followup and patients were asked to transmit all symptomatic episodes.
Comparative Observational Studies
Blandino, 2013^71^ | AF/AT lasting more than 30 seconds documented by an ECG | ECG and 24-hour Holter monitoring during visits. Between visits, all patients were encouraged to document any symptoms suggestive for AF/atrial tachycardia (AT) recurrence by a 12-lead ECG. Furthermore, routinely every month, a physician performed trans-telephonic monitoring
Lan, 2009^68^ | AF (>30 s in duration) documented by 12-lead ECG or Holter | Holter or conventional 12-lead ECG at followup. All patients were followed by telephone and had physical and ECG examinations
Reynolds, 2012^72^ | NR | NR
Rossillo, 2008^73^ | NR | 24-h Holter recording during the first 3 months of followup and daily pulse check
Sang, 2013^69^ | Any symptomatic episodes of documented atrial tachyarrhythmias lasting ≥30 seconds, as well as any episode of asymptomatic atrial tachyarrhythmias lasting ≥10 minutes | 12-lead electrocardiography and 24-hour ambulatory Holter recordings during followup
Sonne, 2009^74^ | AF recurrence was defined as AF that persists 8 weeks after ablation | Measured by serial event recorder transmission and/or Holter monitoring; Patients were asked to transmit their rhythm status three times a day and whenever they experienced symptoms consistent with AF
Yu, 2012^70^ | The AF recurrence was defined as the first documented AF recurrence >30 seconds | Twelve-lead and 24-hour ambulatory electrocardiograph were measured during followup or as soon as the patients first felt recurrent palpitations, whichever event occurred earlier; Ambulatory electrocardiographic recorders were used to correlate symptoms with arrhythmia recurrence
Cryoballoon Ablation vs. Medical
Randomized Controlled Trials
Packer, 2013; Andrade, 2014^75, 103^ | AF occurrence (not defined further) | Personal trans-telephonic monitoring (TTM) systems were provided for weekly scheduled transmissions and recordings at the occurrence of arrhythmia symptoms; Twenty-four-hour Holter monitoring was required at 6 and 12 months.
Cryoballoon Ablation vs. RFA
Randomized Controlled Trials
Herrera Siklody, 2012^81^ | Freedom from AF was defined as no symptoms of AF and no atrial arrhythmias lasting >30 seconds on Holter monitoring after a single procedure | 24-hour Holter monitoring, holter monitoring and exercise testing at followup; Patients with symptoms of AF but no documentation on ECG or Holter monitoring were provided with an event monitor for 8 weeks
Perez-Castellano, 2014^76^ | Clinical or subclinical AF episode ≥2 minutes | Minutes recorded on ECG, Holter monitor, or ICM
Comparative Observational Studies
Chierchia, 2010^77^ | NR | NR
Knecht, 2014^78^ | Episodes of AF (>30 s) or any sustained left atrial tachycardia were counted as recurrences | Physical examination, 12-lead ECG, 24-h Holter monitoring and a 7 day Holter at followup
Kojodjojo, 2010^82^ | Recurrence was defined as any documented episode of AF (both symptomatic and asymptomatic) or atrial tachycardia lasting for more than 30 s | Repeated 24 h Holter monitoring and event recorders
Mandell, 2013^83^ | NR | NR
Mugnai, 2014^79^ | All documented episodes of atrial tachyarrhythmias lasting >30 seconds were considered as recurrence | Physical examinations, electrocardiography, and 24-hour Holter recording performed at followup
Schmidt, 2014^80^ | NR | NR

AF: atrial fibrillation; AT: atrial tachycardia; ECG: electrocardiogram; FU: Followup; ICM: implantable cardiac monitor; NR: not reported; RFA: Radiofrequency Ablation; TTM: trans-telephonic monitoring

Table H8 Ongoing clinical trials

Study (Identifier) | Design | Estimated Completion | AF Type | Special Population | Notes
Cryo vs RFA
Prevention of Atrial Fibrillation by Combined Right Isthmus Ablation and cryoBalloon Pulmonary Vein Isolation in Patients With Typical Atrial Flutter NCT01521988 | RCT Line of therapy NR | June 2015 | Mixed | None | RFA used in both treatment groups.
A Controlled, Prospective, Non-Inferiority, Parallel-Group, Randomised, Interventional, Open, Blinded Outcome Assessment (PROBE-Design), Multi-centre Trial, Comparing Efficacy and Safety of Isolation of the Pulmonary Veins With a Cryoballoon Catheter Versus a Radiofrequency Ablation With a ThermoCool Catheter in Patients With Paroxysmal Atrial Fibrillation NCT01490814 | RCT 2^nd^ line therapy | June 2016 | Paroxysmal | None
Cryoballoon vs. Irrigated Radiofrequency Catheter Ablation: The Effect of Double Short vs. Standard Exposure Cryoablation Duration During Pulmonary Vein Isolation NCT01913522 | RCT 2^nd^ line therapy | January 2017 | Paroxysmal | None
Cryo vs Med
Ablation as First Line Treatment in Paroxysmal Atrial Fibrillation NCT01466842 | RCT 1^st^ line therapy | January 2016 | Paroxysmal | None
Catheter Cryoablation Versus Antiarrhythmic Drug as First-Line Therapy of Paroxysmal Atrial Fibrillation. NCT01803438 | RCT 1^st^ line therapy | June 2017 | Paroxysmal | None
RFA vs Med
Comparison of Treatment of Atrial Fibrillation (AF) Between Surgical Ultrasonic Technology (EPICOR) or Drug Therapy (Cordarone) for Patients With AF Requiring Mitral Valve Surgery NCT01649544 | RCT Line of therapy NR | May 2015 | Mixed | All patients have mitral valvulopathy requiring surgery
Comparison of a Rhythm Control Treatment Strategy Versus a Rate Control Strategy in Patients With Permanent or Long-term | RCT Line of therapy NR | July 2015 | Mixed | All patients had prior cardiac resynchronization therapy | Med group undergoes EEC in addition to med therapy.
Persistent Atrial Fibrillation and Heart Failure Treated With Cardiac Resynchronization Therapy - a Pilot Study NCT01850277 | | | | | Med group has the option to undergo ablation, but is not required of patients.
Ablation vs. Amiodarone for Treatment of Atrial Fibrillation in Patients With Congestive Heart Failure and an Implanted ICD/CRTD NCT00729911 | RCT 2^nd^ line therapy | December 2015 | Mixed | All patients have congestive heart failure and an implanted ICD/CRTD
Atrial Fibrillation Therapy: A Multi-Center Clinical Study NCT01341353 | Non-randomized 1^st^ line therapy | December 2015 | “Symptomatic” | None
Pulmonary Vein Ablation Versus Amiodarone in the Elderly NCT01276093 | RCT 1^st^ and 2^nd^ line therapy | June 2016 | Paroxysmal | All patients >/= 65 years old
A Randomized Ablation-based Atrial Fibrillation Rhythm Control Versus Rate Control Trial in Patients With Heart Failure and High Burden Atrial Fibrillation NCT01420393 | RCT Line of therapy NR | September 2016 | Mixed | All patients have had heart failure
Catheter Ablation Versus Standard Conventional Treatment in Patients With Left Ventricular Dysfunction and Atrial Fibrillation NCT00643188 | RCT 1st and 2nd line therapy | August 2019 | Mixed | All patients have heart failure and an ICD
Other
Catheter Ablation vs Anti-arrhythmic Drug Therapy for Atrial Fibrillation Trial NCT00911508 | RCT 1^st^ line therapy | March 2018 | Mixed | None | Either Cryoablation or RFA used in comparison to med.
Atrial Fibrillation Progression Trial NCT01570361 | RCT 2^nd^ line therapy | June 2018 | Paroxysmal | All patients >/= 60 years old | Either Cryoablation or RFA used in comparison to med.

AF: atrial fibrillation; CRDT: cardiac resynchronization therapy; Cryo: cryoballoon ablation; ICD: Implantable cardiac defibrillator; NR: not reported; RCT: Randomized controlled trial; RFA: Radiofrequency ablation

## References

1 Al-Khatib SM, Allen LaPointe NM, Chatterjee R, et al. Rate-and rhythm-control therapies in patients with atrial fibrillation: a systematic review [Review]. Ann Intern Med. Jun. 3. 2014;160(11):760-773. [pmid: 24887617].
2 Ardagh MW, Pitchford AM, Esson A, et al. Project RED--a successful methodology for improving emergency department performance. N Z Med J. Oct. 14. 2011;124(1344):54-63. [pmid: 22016164].
3 Bertaglia E, Fassini G, Anselmino M, et al. Comparison of ThermoCool Surround Flow catheter versus ThermoCool catheter in achieving persistent electrical isolation of pulmonary veins: a pilot study. Journal of Cardiovascular Electrophysiology. Mar. 2013;24(3):269-273. [pmid: 23210452].
4 Bessiere F, Chevalier P. Pulmonary vein hematoma after atrial fibrillation cryoablation: a new complication. Heart Rhythm. Sep. 2013;10(9):1359. [pmid: 22561845].
5 Bohnen M, Stevenson WG, Tedrow UB, et al. Incidence and predictors of major complications from contemporary catheter ablation to treat cardiac arrhythmias. Heart Rhythm. Nov. 2011;8(11):1661-1666. [pmid: 21699857].
6 Boho A, Misikova S, Spurny P, et al. Complications of circumferential pulmonary vein isolation using the cryoballoon technique: Incidence and predictors. International Journal of Cardiology. Feb. 1. 2014;171(2):217-223. [pmid: 24387893].
7 Bordignon S, Chun KR, Gunawardene M, et al. Comparison of balloon catheter ablation technologies for pulmonary vein isolation: the laser versus cryo study. Journal of Cardiovascular Electrophysiology. Sep. 2013;24(9):987-994. [pmid: 23800359].
8 Brodsky MA. Letter by Brodsky regarding article "Treatment of atrial fibrillation with antiarrhythmic drugs or radiofrequency ablation: two systematic literature reviews and meta-analyses". Circ. Dec. 2009;2(6):e44. author reply e5–6. [pmid: 20009071].
9 Bunch TJ, May HT, Bair TL, et al. Atrial fibrillation ablation patients have long-term stroke rates similar to patients without atrial fibrillation regardless of CHADS2 score. Heart Rhythm. Sep. 2013;10(9):1272-1277. [pmid: 23835257].
10 Camm AJ, Breithardt G, Crijns H, et al. Real-life observations of clinical outcomes with rhythm-and rate-control therapies for atrial fibrillation RECORDAF (Registry on Cardiac Rhythm Disorders Assessing the Control of Atrial Fibrillation). Journal of the American College of Cardiology. Jul. 26. 2011;58(5):493-501. [pmid: 21777747].
11 Chambers D, Rodgers M, Woolacott N. Not only randomized controlled trials, but also case series should be considered in systematic reviews of rapidly developing technologies. J Clin Epidemiol. Dec. 2009;62(12):1253-1260.e4. [pmid: 19349144].
12 Chang CH, Lin JW, Chiu FC, et al. Effect of radiofrequency catheter ablation for atrial fibrillation on morbidity and mortality: a nationwide cohort study and propensity score analysis. Circ. Feb. 2014;7(1):76-82.
13 Da Costa A, Thevenin J, Roche F, et al. Results from the Loire-Ardeche-DromeIsere-Puy-de-Dome (LADIP) Trial on Atrial Flutter, a multicentric prospective randomized study comparing amiodarone and radiofrequency ablation after the first episode of symptomatic atrial flutter. Circulation. 2006;114(16):1676-1681. [pmid: 17030680].
14 De Ponti R, Lumia D, Marazzi R, et al. Left atrial diverticula in patients undergoing atrial fibrillation ablation: morphologic analysis and clinical impact. Journal of Cardiovascular Electrophysiology. Nov. 2013;24(11):1232-1239. [pmid: 23875875].
15 Fasol R, Meinhart J, Binder T. A modified and simplified radiofrequency ablation in patients with mitral valve disease. J Thorac Cardiovasc Surg. Jan. 2005;129(1):215-217. [pmid: 15632848].
16 Gaita F, Leclercq JF, Schumacher B, et al. Incidence of silent cerebral thromboembolic lesions after atrial fibrillation ablation may change according to technology used: comparison of irrigated radiofrequency, multipolar nonirrigated catheter and cryoballoon. Journal of Cardiovascular Electrophysiology. Sep. 2011;22(9):961-968. [pmid: 21453372].
17 Giovannib F, Massimo M, De Lucia L, et al. Catheter ablation of atrial fibrillation in patients with diabetes mellitus type 2: results from a randomized study comparing pulmonary vein isolation versus antiarrhythmic drug therapy. Journal of Cardiovascular Electrophysiology. 2009;20(1):22-28. NEW. [pmid: 18775050].
18 Haeusler KG, Koch L, Herm J, et al. 3 Tesla MRI-detected brain lesions after pulmonary vein isolation for atrial fibrillation: results of the MACPAF study. Journal of Cardiovascular Electrophysiology. Jan. 2013;24(1):14-21. [pmid: 22913568].
19 Hanley CM, Esberg D, Kowey PR. Ablation versus drugs: what is the best first-line therapy for paroxysmal atrial fibrillation? Antiarrhythmic drugs are outmoded and catheter ablation should be the first-line option for all patients with paroxysmal atrial fibrillation: con. Circ. Aug. 2014;7(4):74754.
20 Herm J, Fiebach JB, Koch L, et al. Neuropsychological effects of MRI-detected brain lesions after left atrial catheter ablation for atrial fibrillation: long-term results of the MACPAF study. Circ. Oct. 2013;6(5):843-850. [pmid: 23989301].
21 Hindricks G, Packer DL. Moving catheter ablation forward from paroxysmal to persistent atrial fibrillation: progress, limitations, and surprises of the SARA trial. European heart journal. Feb. 2014;35(8):4824.
22 Hussein AA, Wazni OM, Harb S, et al. Radiofrequency ablation of atrial fibrillation in patients with mechanical mitral valve prostheses safety, feasibility, electrophysiologic findings, and outcomes. Journal of the American College of Cardiology. Aug. 2. 2011;58(6):596-602. [pmid: 21798422].
23 Jones DG, Wong T. Catheter ablation versus rate control for atrial fibrillation: what have we learnt from the ARC-HF trial? [Review]. Future Cardiology. Sep. 2013;9(5):599-602. [pmid: 24020656].
24 Kaba RA, Cannie D, Ahmed O. RAAFT-2: Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of paroxysmal atrial fibrillation. Global Cardiology Science and Practice. 2014;2. NEW.
25 Khaykin Y, Skanes A, Champagne J, et al. A randomized controlled trial of the efficacy and safety of electroanatomic circumferential pulmonary vein ablation supplemented by ablation of complex fractionated atrial electrograms versus potential-guided pulmonary vein antrum isolation guided by intracardiac ultrasound. Circ. Oct. 2009;2(5):481-487. [pmid: 19843915].
26 Khaykin Y, Wang X, Natale A, et al. Cost comparison of ablation versus antiarrhythmic drugs as first-line therapy for atrial fibrillation: an economic evaluation of the RAAFT pilot study. Journal of Cardiovascular Electrophysiology. Jan. 2009;20(1):7-12. [pmid: 18803564].
27 Khurram IM, Dewire J, Mager M, et al. Relationship between left atrial appendage morphology and stroke in patients with atrial fibrillation. Heart Rhythm. Dec. 2013;10(12):1843-1849. [pmid: 24076444].
28 Kim JB, Cho W-C, Jung SH, et al. Alternative energy sources for surgical treatment of atrial fibrillation in patients undergoing mitral valve surgery: microwave ablation vs cryoablation. J Korean Med Sci. Oct. 2010;25(10):1467-1472. [pmid: 20890428].
29 Koch L, Haeusler KG, Herm J, et al. Mesh ablator vs. cryoballoon pulmonary vein ablation of symptomatic paroxysmal atrial fibrillation: results of the MACPAF study. Europace. Oct. 2012;14(10):1441-1449. [pmid: 22523379].
30 Kosiuk J, Nedios S, Kornej J, et al. Impact of left atrial appendage morphology on periinterventional thromboembolic risk during catheter ablation of atrial fibrillation. Heart Rhythm. 2014;11(9):1522-1527. NEW. [pmid: 24858813].
31 Kuhne M, Schaer B, Ammann P, et al. Cryoballoon ablation for pulmonary vein isolation in patients with paroxysmal atrial fibrillation. Swiss Med Wkly. Apr. 17. 2010;140(15–16):214-221. [pmid: 20407957].
32 Li X, Wissner E, Kamioka M, et al. Safety and feasibility of transseptal puncture for atrial fibrillation ablation in patients with atrial septal defect closure devices. Heart Rhythm. Feb. 2014;11(2):330-335. [pmid: 24239844].
33 Lin YJ, Tai CT, Chang SL, et al. Efficacy of additional ablation of complex fractionated atrial electrograms for catheter ablation of nonparoxysmal atrial fibrillation. Journal of Cardiovascular Electrophysiology. Jun. 2009;20(6):607-615. UPDATE. [pmid: 19642225].
34 Lin Z, Shan ZG, Liao CX, et al. The effect of microwave and bipolar radio-frequency ablation in the surgical treatment of permanent atrial fibrillation during valve surgery. Thorac Cardiovasc Surg. Dec. 2011;59(8):460-464. [pmid: 21692021].
35 Linhart M, Bellmann B, Mittmann-Braun E, et al. Comparison of cryoballoon and radiofrequency ablation of pulmonary veins in 40 patients with paroxysmal atrial fibrillation: a case-control study. Journal of Cardiovascular Electrophysiology. Dec. 2009;20(12):1343-1348. [pmid: 19656254].
36 Liu Z, Ling Z, Su L, et al. The effect of different treatment strategies on left atrial size in patients with lone paroxysmal atrial fibrillation-a prospective cohort study. Journal of Interventional Cardiac Electrophysiology. Dec. 2008;23(3):167-173. [pmid: 18810622].
37 Magnani JW, Benjamin EJ. Where do we come from? Where are we going? Adverse outcomes in catheter ablation for atrial fibrillation. Circ. Apr. 2014;7(2):195-197.
38 Malmborg H, Lonnerholm S, Blomstrom P, et al. Ablation of atrial fibrillation with cryoballoon or duty-cycled radiofrequency pulmonary vein ablation catheter: a randomized controlled study comparing the clinical outcome and safety; the AF-COR study. Europace. Nov. 2013;15(11):1567-1573. [pmid: 23703361].
39 Marrouche NF, Guenther J, Segerson NM, et al. Randomized comparison between open irrigation technology and intracardiac-echoguided energy delivery for pulmonary vein antrum isolation: procedural parameters, outcomes, and the effect on esophageal injury. Journal of Cardiovascular Electrophysiology. Jun. 2007;18(6):583-588. [pmid: 17490437].
40 Martin F, Jan C, Renata N, et al. Pulmonary vein isolation using segmental versus electroanatomical circumferential ablation for paroxysmal atrial fibrillation: over 3year results of a prospective randomized study. Journal of Interventional Cardiac Electrophysiology. 2008;22(1):13-21. NEW. [pmid: 18418704].
41 Metzner A, Wissner E, Schoonderwoerd B, et al. The influence of varying energy settings on efficacy and safety of endoscopic pulmonary vein isolation. Heart Rhythm. Sep. 2012;9(9):1380-1385. [pmid: 22472520].
42 Neumann T, Kuniss M, Conradi G, et al. MEDAFI-Trial (Micro-embolization during ablation of atrial fibrillation): comparison of pulmonary vein isolation using cryoballoon technique vs. radiofrequency energy. Europace. Jan. 2011;13(1):37-44. [pmid: 20829189].
43 Phan K, Xie A, La Meir M, et al. Surgical ablation for treatment of atrial fibrillation in cardiac surgery: a cumulative meta-analysis of randomised controlled trials [Review]. Heart. May. 2014;100(9):722-730. [pmid: 24650881].
44 Piccini JP, Stevens SR, Lokhnygina Y, et al. Outcomes after cardioversion and atrial fibrillation ablation in patients treated with rivaroxaban and warfarin in the ROCKET AF trial. Journal of the American College of Cardiology. May. 2013;61(19):1998-2006. NEW. [pmid: 23500298].
45 Richter B, Gwechenberger M, Socas A, et al. Frequency of recurrence of atrial fibrillation within 48 hours after ablation and its impact on long-term outcome. American Journal of Cardiology. Mar. 15. 2008;101(6):843-847. [pmid: 18328850].
46 Roberts A. Atrial fibrillation: Catheter ablation as a first-line AF therapy: the RAAFT-2 trial. Nature Reviews Cardiology. Apr. 2014;11(4):188.
47 Sauren LD, Van Belle Y, De Roy L, et al. Transcranial measurement of cerebral microembolic signals during endocardial pulmonary vein isolation: comparison of three different ablation techniques. Journal of Cardiovascular Electrophysiology. Oct. 2009;20(10):1102-1107. [pmid: 19549035].
48 Schmidt B, Gunawardene M, Krieg D, et al. A prospective randomized single-center study on the risk of asymptomatic cerebral lesions comparing irrigated radiofrequency current ablation with the cryoballoon and the laser balloon. Journal of Cardiovascular Electrophysiology. Aug. 2013;24(8):869-874. [pmid: 23601001].
49 Tse HF, Kwong YL, Lau CP. Transvenous cryoablation reduces platelet activation during pulmonary vein ablation compared with radiofrequency energy in patients with atrial fibrillation. Journal of Cardiovascular Electrophysiology. Oct. 2005;16(10):106470. UPDATE.
50 US Food and Drug Administration (FDA). Summary of Safety and Effectiveness Data (SSED): Arctic Front Cardiac CryoAblation Catheter System, accessed 10/24/12 at http://www.accessdata.fda.gov/cdrh_docs/pdf10/P100010b.pdf. 2010.
51 Wissner E, Metzner A, Neuzil P, et al. Asymptomatic brain lesions following laserballoon-based pulmonary vein isolation. Europace. Feb. 2014;16(2):214-219. [pmid: 23933850].
52 Won H, Kim JY, Shim J, et al. Effect of a single bolus injection of low-dose hydrocortisone for prevention of atrial fibrillation recurrence after radiofrequency catheter ablation. Circulation Journal. 2013;77(1):53-59. NEW. [pmid: 23006726].
53 Xu J, Huang Y, Cai H, et al. Is cryoballoon ablation preferable to radiofrequency ablation for treatment of atrial fibrillation by pulmonary vein isolation? A meta-analysis. PLoS ONE [Electronic Resource]. 2014;9(2):e90323.
54 Cosedis Nielsen J, Johannessen A, Raatikainen P, et al. Radiofrequency ablation as initial therapy in paroxysmal atrial fibrillation. N Engl J Med. Oct. 25. 2012;367(17):1587-1595. [pmid: 23094720].
55 Jais P, Cauchemez B, Macle L, et al. Catheter ablation versus antiarrhythmic drugs for atrial fibrillation: the A4 study.[Erratum appears in Circulation. 2009 Sep 8;120(10):e83]. Circulation. Dec. 9. 2008;118(24):2498-2505. [pmid: 19029470].
56 Morillo CA, Verma A, Connolly SJ, et al. Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of paroxysmal atrial fibrillation (RAAFT-2): a randomized trial. JAMA. Feb. 19. 2014;311(7):692-700. [pmid: 24549549].
57 Pappone C, Augello G, Sala S, et al. A randomized trial of circumferential pulmonary vein ablation versus antiarrhythmic drug therapy in paroxysmal atrial fibrillation: the APAF Study. Journal of the American College of Cardiology. Dec. 5. 2006;48(11):2340-2347. [pmid: 17161267].
58 Pappone C, Vicedomini G, Augello G, et al. Radiofrequency catheter ablation and antiarrhythmic drug therapy: a prospective, randomized, 4-year follow-up trial: the APAF study. Circ. Dec. 2011;4(6):808-814. [pmid: 21946315].
59 Wazni OM, Marrouche NF, Martin DO, et al. Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of symptomatic atrial fibrillation: a randomized trial. JAMA. Jun. 1. 2005;293(21):2634-2640. [pmid: 15928285].
60 Wilber DJ, Pappone C, Neuzil P, et al. Comparison of antiarrhythmic drug therapy and radiofrequency catheter ablation in patients with paroxysmal atrial fibrillation: a randomized controlled trial. JAMA. Jan. 27. 2010;303(4):333-340. [pmid: 20103757].
61 Hunter RJ, Berriman TJ, Diab I, et al. A randomized controlled trial of catheter ablation versus medical treatment of atrial fibrillation in heart failure (the CAMTAF trial). Circ Arrhythm Electrophysiol. Feb. 2014;7(1):31-38. [pmid: 24382410].
62 MacDonald MR, Connelly DT, Hawkins NM, et al. Radiofrequency ablation for persistent atrial fibrillation in patients with advanced heart failure and severe left ventricular systolic dysfunction: a randomised controlled trial. Heart. May. 2011;97(9):740-747. [pmid: 21051458].
63 Mont L, Bisbal F, Hernandez-Madrid A, et al. Catheter ablation vs. antiarrhythmic drug treatment of persistent atrial fibrillation: a multicentre, randomized, controlled trial (SARA study). European heart journal. 2013. Oct. 17. [pmid: 24135832].
64 Oral H, Pappone C, Chugh A, et al. Circumferential pulmonary-vein ablation for chronic atrial fibrillation. N Engl J Med. Mar. 2. 2006;354(9):934-941. [pmid: 16510747].
65 Jones DG, Haldar SK, Hussain W, et al. A randomized trial to assess catheter ablation versus rate control in the management of persistent atrial fibrillation in heart failure. Journal of the American College of Cardiology. 2013;61(18):1894-1903. NEW. [pmid: 23500267].
66 Forleo GB, Mantica M, De Luca L, et al. Catheter ablation of atrial fibrillation in patients with diabetes mellitus type 2: results from a randomized study comparing pulmonary vein isolation versus antiarrhythmic drug therapy. Journal of Cardiovascular Electrophysiology. Jan. 2009;20(1):22-28. [pmid: 18775050].
67 Stabile G, Bertaglia E, Senatore G, et al. Catheter ablation treatment in patients with drug-refractory atrial fibrillation: a prospective, multi-centre, randomized, controlled study (Catheter Ablation For The Cure Of Atrial Fibrillation Study). European heart journal. Jan. 2006;27(2):216-221. [pmid: 16214831].
68 Lan X, Su L, Ling Z, et al. Catheter ablation vs. amiodarone plus losartan for prevention of atrial fibrillation recurrence in patients with paroxysmal atrial fibrillation. Eur J Clin Invest. Aug. 2009;39(8):657-663. [pmid: 19490069].
69 Sang C-H, Chen K, Pang X-F, et al. Depression, anxiety, and quality of life after catheter ablation in patients with paroxysmal atrial fibrillation. Clin Cardiol. Jan. 2013;36(1):40-45. [pmid: 22777577].
70 Yu S, Zhao Q, Wu P, et al. Effect of anxiety and depression on the recurrence of paroxysmal atrial fibrillation after circumferential pulmonary vein ablation. Journal of Cardiovascular Electrophysiology. Nov. Suppl 1. 2012;23:S17-S23. [pmid: 22998234].
71 Blandino A, Toso E, Scaglione M, et al. Long-term efficacy and safety of two different rhythm control strategies in elderly patients with symptomatic persistent atrial fibrillation. Journal of Cardiovascular Electrophysiology. Jul. 2013;24(7):731-738. [pmid: 23551460].
72 Reynolds MR, Gunnarsson CL, Hunter TD, et al. Health outcomes with catheter ablation or antiarrhythmic drug therapy in atrial fibrillation: results of a propensity-matched analysis. Circ Cardiovasc Qual Outcomes. Mar. 1. 2012;5(2):171-181. [pmid: 22373904].
73 Rossillo A, Bonso A, Themistoclakis S, et al. Role of anticoagulation therapy after pulmonary vein antrum isolation for atrial fibrillation treatment. J Cardiovasc Med (Hagerstown). Jan. 2008;9(1):51-55. [pmid: 18268419].
74 Sonne K, Patel D, Mohanty P, et al. Pulmonary vein antrum isolation, atrioventricular junction ablation, and antiarrhythmic drugs combined with direct current cardioversion: survival rates at 7 years follow-up. J Interv Card Electrophysiol. Nov. 2009;26(2):121-126. [pmid: 19789970].
75 Packer DL, Irwin JM, Champagne J. Cryoballoon ablation of pulmonary veins for paroxysmal atrial fibrillation: first results of the North American Arctic Front STOP-AF pivotal trial. J Am Coll Cardiol. 2010;55:E3015-E3016.
76 Perez-Castellano N, Fernandez-Cavazos R, Moreno J, et al. The COR trial: a randomized study with continuous rhythm monitoring to compare the efficacy of cryoenergy and radiofrequency for pulmonary vein isolation. Heart Rhythm. Jan. 2014;11(1):8-14. [pmid: 24103221].
77 Chierchia GB, Capulzini L, Droogmans S, et al. Pericardial effusion in atrial fibrillation ablation: a comparison between cryoballoon and radiofrequency pulmonary vein isolation. Europace. Mar. 2010;12(3):337-341. [pmid: 20056597].
78 Knecht S, Sticherling C, von Felten S, et al. Long-term comparison of cryoballoon and radiofrequency ablation of paroxysmal atrial fibrillation: a propensity score matched analysis. Int J Cardiol. Oct. 20. 2014;176(3):645-650. [pmid: 25149399].
79 Mugnai G, Chierchia GB, de Asmundis C, et al. Comparison of pulmonary vein isolation using cryoballoon versus conventional radiofrequency for paroxysmal atrial fibrillation. The American journal of cardiology. May. 1. 2014;113(9):1509-1513. [pmid: 24630388].
80 Schmidt M, Dorwarth U, Andresen D, et al. Cryoballoon versus RF ablation in paroxysmal atrial fibrillation: results from the German Ablation Registry. J Cardiovasc Electrophysiol. Jan. 2014;25(1):1-7. [pmid: 24134539].
81 Herrera Siklody C, Deneke T, Hocini M, et al. Incidence of asymptomatic intracranial embolic events after pulmonary vein isolation: comparison of different atrial fibrillation ablation technologies in a multicenter study. Journal of the American College of Cardiology. Aug. 9. 2011;58(7):681-688. [pmid: 21664090].
82 Kojodjojo P, O'Neill MD, Lim PB, et al. Pulmonary venous isolation by antral ablation with a large cryoballoon for treatment of paroxysmal and persistent atrial fibrillation: medium-term outcomes and non-randomised comparison with pulmonary venous isolation by radiofrequency ablation. Heart. Sep. 2010;96(17):1379-1384. [pmid: 20801856].
83 Mandell J, Amico F, Parekh S, et al. Early experience with the cryoablation balloon procedure for the treatment of atrial fibrillation by an experienced radiofrequency catheter ablation center. J Invasive Cardiol. Jun. 2013;25(6):288-292. [pmid: 23735354].
84 Baman TS, Jongnarangsin K, Chugh A, et al. Prevalence and predictors of complications of radiofrequency catheter ablation for atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2011;22(6):626-631. [pmid: 21235674].
85 Bertaglia E, Zoppo F, Tondo C, et al. Early complications of pulmonary vein catheter ablation for atrial fibrillation: a multicenter prospective registry on procedural safety. Heart Rhythm. Oct. 2007;4(10):1265-1271. [pmid: 17905330].
86 Bunch TJ, Crandall BG, Weiss JP, et al. Patients treated with catheter ablation for atrial fibrillation have long-term rates of death, stroke, and dementia similar to patients without atrial fibrillation. Journal of Cardiovascular Electrophysiology. Aug. 2011;22(8):839-845. [pmid: 21410581].
87 Dagres N, Hindricks G, Kottkamp H, et al. Complications of atrial fibrillation ablation in a high-volume center in 1,000 procedures: still cause for concern?. Journal of Cardiovascular Electrophysiology. Sep. 2009;20(9):1014-1019. [pmid: 19490383].
88 Hao SC, Hunter TD, Gunnarsson C, et al. Acute safety outcomes in younger and older patients with atrial fibrillation treated with catheter ablation. J Interv Card Electrophysiol. Nov. 2012;35(2):173-182. [pmid: 22714547].
89 Deshmukh A, Patel NJ, Pant S, et al. In-hospital complications associated with catheter ablation of atrial fibrillation in the United States between 2000 and 2010: analysis of 93 801 procedures. Circulation. 2013;128(19):2104-2112. [pmid: 24061087].
90 Hoyt H, Bhonsale A, Chilukuri K, et al. Complications arising from catheter ablation of atrial fibrillation: temporal trends and predictors. Heart Rhythm. Dec. 2011;8(12):1869-1874. [pmid: 21798230].
91 Hunter RJ, McCready J, Diab I, et al. Maintenance of sinus rhythm with an ablation strategy in patients with atrial fibrillation is associated with a lower risk of stroke and death. Heart. Jan. 2012;98(1):48-53. [pmid: 21930724].
92 Piccini JP, Sinner MF, Greiner MA, et al. Outcomes of Medicare beneficiaries undergoing catheter ablation for atrial fibrillation. Circulation. Oct. 30. 2012;126(18):2200-2207. [pmid: 23019293].
93 Shah RU, Freeman JV, Shilane D, et al. Procedural complications, rehospitalizations, and repeat procedures after catheter ablation for atrial fibrillation. J Am Coll Cardiol. Jan. 10. 2012;59(2):143-149. [pmid: 22222078].
94 Srivatsa UN, Danielsen B, Anderson I, et al. Risk predictors of stroke and mortality after ablation for atrial fibrillation: The California experience 2005–2009. Heart Rhythm. Nov. 2014;11(11):1898-1903. [pmid: 25048442].
95 Kosiuk J, Kornej J, Bollmann A, et al. Early cerebral thromboembolic complications after radiofrequency catheter ablation of atrial fibrillation: Incidence, characteristics, and risk factors. Heart Rhythm. Nov. 2014;11(11):1934-1940. [pmid: 25086257].
96 D'Ascenzo F, Corleto A, Biondi-Zoccai G, et al. Which are the most reliable predictors of recurrence of atrial fibrillation after transcatheter ablation?: a meta-analysis. International Journal of Cardiology. Sep. 1. 2013;167(5):1984-1989. [pmid: 22626840].
97 Zado E, Callans DJ, Riley M, et al. Longterm clinical efficacy and risk of catheter ablation for atrial fibrillation in the elderly. J Cardiovasc Electrophysiol. Jun. 2008;19(6):621-626. [pmid: 18462325].
98 Michowitz Y, Rahkovich M, Oral H, et al. Effects of sex on the incidence of cardiac tamponade after catheter ablation of atrial fibrillation: results from a worldwide survey in 34 943 atrial fibrillation ablation procedures. Circ Arrhythm Electrophysiol. Apr. 2014;7(2):274-280. [pmid: 24519888].
99 Gibson DN, Di Biase L, Mohanty P, et al. Stiff left atrial syndrome after catheter ablation for atrial fibrillation: clinical characterization, prevalence, and predictors.[Erratum appears in Heart Rhythm. 2011 Nov;8(11)1828]. Heart Rhythm. Sep. 2011;8(9):1364-1371. [pmid: 21354332].
100 Sacher F, Monahan KH, Thomas SP, et al. Phrenic nerve injury after atrial fibrillation catheter ablation: characterization and outcome in a multicenter study. J Am Coll Cardiol. Jun. 20. 2006;47(12):2498-2503. [pmid: 16781380].
101 Wynn GJ, Das M, Bonnett LJ, et al. Qualityof-life benefits of catheter ablation of persistent atrial fibrillation: a reanalysis of data from the SARA study. Europace. 2014. Jul. 15. [pmid: 25028177].
102 Reynolds MR, Walczak J, White SA, et al. Improvements in symptoms and quality of life in patients with paroxysmal atrial fibrillation treated with radiofrequency catheter ablation versus antiarrhythmic drugs. Circ Cardiovasc Qual Outcomes. Nov. 2010;3(6):615-623. [pmid: 20940250].
103 Andrade JG, Khairy P, Macle L, et al. Incidence and significance of early recurrences of atrial fibrillation after cryoballoon ablation: insights from the multicenter Sustained Treatment of Paroxysmal Atrial Fibrillation (STOP AF) Trial. Circ Arrhythm Electrophysiol. Feb. 2014;7(1):69-75. [pmid: 24446022].