# Strength of Evidence Tables

Table G1 Strength of evidence for KQ1: What is the comparative efficacy and effectiveness of AF catheter ablation on long- (>12 months) term outcomes in the general adult and Medicare populations? Consider (a) Catheter ablation versus medical therapy: Radiofrequency ablation (RFA) versus medical therapy

Long-term (>12 months) Efficacy and Effectiveness, KQ 1a: RFA Versus Medical Therapy | Number of Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Grade
Mortality (all cause) >30 days
Paroxysmal AF
RCTs | 2 RCTs (N = 408) | medium | direct | unknown | imprecise | undetected | Low
Observational | None | - | - | - | - | - | Insufficient
Persistent AF
RCTs | None | - | - | - | - | - | Insufficient
Observational (Medicare population) | 1 (N = 412) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Mixed population
RCTs | None | - | - | - | - | - | Insufficient
Observational (general population) | 1 (N = 170) | medium | direct | consistent | imprecise | undetected | Insufficient^*^
Observational (Medicare population) | 1 (N = 351) | high | direct | unknown | imprecise | undetected | Insufficient^*^
Stroke >30 days
Paroxysmal AF
RCTs | 1 (N = 127) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Observational | None | - | - | - | - | - | Insufficient
Persistent AF
RCTs | None | - | - | - | - | - | Insufficient
Observational (Medicare population) | 1 (N = 412) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Mixed population
RCTs | None | - | - | - | - | - | Insufficient
Observational | 1 (N = 170) | medium | direct | consistent | imprecise | undetected | Insufficient^*^
Observational (Medicare population) | 1 (N = 351) | high | direct | unknown | imprecise | undetected | Insufficient^*^
MI >30 days
Paroxysmal AF
RCTs | 1 (N = 294) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Observational | None | - | - | - | - | - | Insufficient
Persistent AF
RCTs | None | - | - | - | - | - | Insufficient
Observational (Medicare population) | 1 (N = 412) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Mixed population
RCTs | None | - | - | - | - | - | Insufficient
Observational (Medicare population) | 1 (N = 351) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Congestive Heart Failure
Paroxysmal
RCTs | 1 (N = 294) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Persistent AF
Observational (Medicare population) | 1 (N = 412) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Mixed AF
Observational (Medicare population) | 1 (N = 351) | high | direct | unknown | imprecise | undetected | Insufficient^*^
Health Related Quality of Life: SF-36
Mental Component Score
Paroxysmal AF
RCTs | 1 (N = 294) at 24 months; 1 (N = 198) at 48 months | medium | direct | consistent | imprecise | undetected | Insufficient^*^
Persistent AF, Mixed population | None | - | - | - | - | - | Insufficient
Physical Component Score
Paroxysmal AF
RCTs | 1 (N = 294) at 24 months; 1 (N = 198) at 48 months | medium | direct | consistent | precise | undetected | Insufficient^*^
Persistent AF, Mixed population | None | - | - | - | - | - | Insufficient
Other HRQOL Measures
Minnesota Living with Heart Failure Questionnaire
Persistent AF (CHF patients)
RCTs | 1 (N = 52) at 12 months | medium | direct | unknown | imprecise | undetected | Insufficient
Observational studies | None | - | - | - | - | - | Insufficient
Paroxysmal AF, Mixed population | None | - | - | - | - | - | Insufficient
Freedom from recurrence (any arrhythmia)
Paroxysmal AF
RCTs | 3 (N = 619) | medium | indirect | consistent | precise | undetected | Moderate
Persistent AF | None | - | - | - | - | - | Insufficient
Mixed population
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 1 (N = 85 in RFA arm) | high | indirect | unknown | imprecise | suspected | Insufficient^*^
Maintenance of sinus rhythm
Paroxysmal | None | - | - | - | - | - | Insufficient
Persistent
RCTs | None | - | - | - | - | - | Insufficient
Observational (Medicare population) | 1 (N = 412) | high | indirect | unknown | precise | undetected | Insufficient^*^
Mixed population
RCTs | None | - | - | - | - | - | Insufficient
Observational | 1 (N = 170) | high | indirect | unknown | imprecise | suspected | Insufficient^*^
Reablation (any arrhythmia)
Paroxysmal
RCTs | 4 (N = 337) | medium | indirect | inconsistent | imprecise | undetected | Low
Observational | None | - | - | - | - | - | Insufficient
Persistent
RCTs | None | - | - | - | - | - | Insufficient
Observational (Medicare population) | 1 (N = 153 ablation group only) | medium | direct | unknown | imprecise | undetected | Insufficient^*^

AAD = Antiarrhythmic drug; AF = atrial fibrillation; CHF = chronic heart failure; KQ = Key Question; MLHFQ = Minnesota living with heart failure questionnaire; RCT = randomized controlled trial; RFA = radiofrequency catheter ablation.

* Conclusions are not possible secondary to study limitations (i.e. methodology), small sample sizes resulting in low precision of estimates and/or limited data from single studies.

Table G2 Key findings and strength of evidence for Key Question (KQ) 1: What is the comparative efficacy and effectiveness of AF catheter ablation on short- (≤12 months) term outcomes in the general adult and Medicare populations? Consider (a) Catheter ablation versus medical therapy: radiofrequency ablation (RFA) versus medical therapy

Short-term (≤12 months) Efficacy and Effectiveness, KQ 1a: RFA Versus Medical Therapy | Number of Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Grade
Mortality (all cause) >30 days
All RCTs (regardless of AF type) | 7 (N = 814) | medium | direct | inconsistent | imprecise | undetected | Low
Paroxysmal AF
RCTs | 3 (N = 333) | medium | direct | inconsistent | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Persistent AF
RCTs | 3 (N = 344) | medium | direct | consistent | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Mixed population
RCTs | 1 (N = 137) | low | direct | unknown | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Stroke >30 days
All RCTs (regardless of AF type)
Paroxysmal AF
RCTs | 1 (N = 67) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Observational studies | None | - | - | - | - | - | Insufficient
Persistent AF
RCTs | 1 (N = 146) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Observational studies | None | - | - | - | - | - | Insufficient
Mixed population
RCTs | 1 (N = 70) (Diabetic patients) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Observational studies | None | - | - | - | - | - | Insufficient
Myocardial infarction >30 days
Paroxysmal AF
RCTs | 2 (N = 270) | medium | direct | unknown | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Persistent AF, Mixed population | None | - | - | - | - | - | Insufficient
Congestive heart failure
Paroxysmal AF, Persistent AF and Mixed population | None | - | - | - | - | - | Insufficient
Health related quality of life (HRQOL): SF- 36
Mental Component Score
Paroxysmal AF
RCTs | 2 (N = 406) | medium | direct | consistent | imprecise | undetected | Insufficient^*^
Observational studies | 1 (N = 166) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Persistent AF
RCTs | 1 (N = 41) at 6 months | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Observational studies | None | - | - | - | - | - | Insufficient
Physical Component Score
Paroxysmal AF
RCTs | 2 (N = 406) | medium | direct | consistent | imprecise | undetected | Insufficient^*^
Observational studies | 1 (N = 166) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Persistent AF
RCTs | 1 (N = 41) at 6 months (heart failure) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Observational studies | None | - | - | - | - | - | Insufficient
Mixed population | None | - | - | - | - | - | Insufficient
Other HROQL Measures
Minnesota Living with Heart Failure Questionnaire
Persistent AF
RCTs | 3 (N = 141) (Heart failure) | medium | direct | unknown | imprecise | undetected | Insufficient
Observational studies | None | - | - | - | - | - | Insufficient
Paroxysmal AF, Mixed population | None | - | - | - | - | - | Insufficient
EuroQOL-5D and Symptom Check List
Paroxysmal AF
RCTs | 1 (N = 127) EQ5D; 1 (N = 112) Symptom Check List | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Observational studies | None | - | - | - | - | - | Insufficient
Persistent AF, Mixed population | None | - | - | - | - | - | Insufficient
AFQOL and KCCQ
Persistent AF
RCTs | 1 (N = 146) AF-QOL; 1 (N = 127) KCCQ | medium | direct | consistent | imprecise | undetected | Insufficient^*^
Observational studies | None | - | - | - | - | - | Insufficient
Paroxysmal AF, Mixed population | None | - | - | - | - | - | Insufficient
Zung Self-Rating Anxiety Scale (SAS)
Paroxysmal AF
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 2 (N = 365) | medium | direct | consistent | imprecise | undetected | Insufficient^*^
Persistent AF, Mixed population | None | - | - | - | - | - | Insufficient
Zung Self-Rating Depression Scale (SDS)
Paroxysmal AF
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 2 (N = 365) | medium | direct | consistent | imprecise | undetected | Insufficient^*^
Persistent AF, Mixed population | None | - | - | - | - | - | Insufficient
Freedom from recurrence (any arrhythmia)
All RCTs (regardless of AF type) | 9 (N = 1089) | medium | indirect | consistent | precise | undetected | Moderate
Paroxysmal AF
RCTs | 4 (N = 538) | medium | indirect | consistent | precise | undetected | Moderate
Observational | 2 (N = 322) | medium | indirect | inconsistent | imprecise | undetected | Insufficient
Persistent AF
RCTs | 3 (N = 344) | medium | indirect | inconsistent | imprecise | undetected | Low
Observational | None | - | - | - | - | - | Insufficient
Mixed Population
RCTs | 2 (N = 207) | medium | indirect | consistent | imprecise | undetected | Low
Maintenance of sinus rhythm
Paroxysmal AF
RCTs | 2 (N = 310) | medium | indirect | inconsistent | precise | undetected | Low
Observational studies | 2 (N = 385) | high | indirect | unknown | imprecise | undetected | Insufficient^*^
Persistent AF
RCTs | 2 (N = 93) | medium | indirect | consistent | imprecise | undetected | Low
Reablation (post-blanking period)
All RCTs (regardless of AF type) | 8 (N = 430) (ablation group only) | medium | indirect | inconsistent | imprecise | undetected | Low
Paroxysmal AF
RCTs | 3 (N = 184) (ablation group only) | medium | indirect | inconsistent | imprecise | undetected | Low
Observational studies | 1 (N = 82) (ablation group only) | - | - | - | - | - | Insufficient
Persistent AF
RCTs | 5 (N = 246) (ablation group only) | medium | indirect | inconsistent | imprecise | undetected | Low
(patients with heart failure) | 3 RCTs (N = 71) (ablation group only) | medium | indirect | inconsistent | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Mixed population | None | - | - | - | - | - | Insufficient

AF = atrial fibrillation; KQ = Key Question; RCT = randomized controlled trial; RFA = radiofrequency catheter ablation.

* Conclusions are not possible secondary to study limitations, small sample sizes resulting in low precision of estimates and/or limited data from single studies.

Table G3 Key findings and strength of evidence for Key Question 1: What is the comparative efficacy and effectiveness of AF catheter ablation on short- (≤12 months) term outcomes in the general adult and Medicare populations? Consider (a) Catheter ablation versus medical therapy: Cryoballoon ablation versus medical therapy

Short-Term (≤12 months) Efficacy, KQ 1a: Cryoballoon ablation Versus Medical Therapy | Number of Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Grade
All outcomes are for the same RCT in a mixed population
Mortality (all cause) >30 days
Paroxysmal AF, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed Population
RCTs | 1 (N = 245) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Stroke >30 days
Paroxysmal AF, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed Population
RCTs | 1 (N = 245) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
MI >30 days
Paroxysmal AF, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed Population
RCTs | 1 (N = 245) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Congestive Heart Failure
Paroxysmal AF, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed Population
RCTs | 1 (N = 245) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Health Related Quality of Life
Paroxysmal AF, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed Population
RCTs | 1 (N = 245) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Freedom From Protocol-Defined Treatment Failure
Paroxysmal AF, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed Population
RCTs | 1 (N=245) | medium | direct | unknown | precise | undetected | Low^†^
Maintenance of Sinus Rhythm | None | - | - | - | - | - | Insufficient

AF = atrial fibrillation; KQ = Key Question; RCT = randomized controlled trial; RFA = radiofrequency catheter ablation.

* Conclusions are not possible secondary to study limitations, small sample sizes resulting in low precision of estimates and/or limited data from single studies.

† Upgraded for a large effect size.

Table G4 Key findings and strength of evidence for Key Question 1: Long-term (>12 months) efficacy and effectiveness outcomes comparing cryoballoon ablation with RFA for AF

Long-Term (> 12 months) Efficacy, KQ 1a: Cryoballoon ablation RFA | Number of Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Grade
Mortality (all cause) > 30 days
Paroxysmal AF
RCTs | None | - | - | - | - | - | Insufficient
Observational | 1 (N = 396) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Persistent AF, Mixed Population | None | - | - | - | - | - | Insufficient
Freedom from AF Recurrence
Paroxysmal AF
RCTs | None | - | - | - | - | - | Insufficient
Observational | 2 (N = 538) | medium | direct | consistent | imprecise | undetected | Insufficient^*^
Persistent AF | None | - | - | - | - | - | Insufficient
Mixed Population
RCTs | None | - | - | - | - | - | Insufficient
Observational
Reablation
Paroxysmal, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed Population
RCTs | None | - | - | - | - | - | Insufficient
Observational | 1 (N = 177) | medium | direct | unknown | imprecise | undetected | Insufficient^*^

AF = atrial fibrillation; KQ = Key Question; RFA = radiofrequency ablation.

* Conclusions are not possible secondary to study limitations, small sample sizes resulting in low precision of estimates and/or limited data from single studies.

Table G5 Key findings and strength of evidence for Key Question 1: Short-term (≤12 months) efficacy and effectiveness outcomes comparing cryoballoon ablation with RFA for AF

Short-Term (≤ 12 months) Efficacy, KQ 1a: Cryoballoon ablation RFA | Number of Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Grade
Freedom from AF Recurrence
Paroxysmal AF
RCTs | 1 (N = 50) | medium | indirect | unknown | imprecise | undetected | Insufficient^*^
Observational studies | 1 (N=177) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Persistent AF | None | - | - | - | - | - | Insufficient
Mixed Population
RCTs | 1 (N =60) | medium | indirect | unknown | imprecise | undetected | Insufficient^*^
Observational studies | None | - | - | - | - | - | Insufficient
Reablation
Paroxysmal AF
RCTs | 1 (N = 50) | medium | indirect | unknown | imprecise | undetected | Insufficient^*^
Observational studies | None | - | - | - | - | - | Insufficient
Persistent AF | None | - | - | - | - | - | Insufficient
Mixed
RCTs | 1 (N =60) | medium | indirect | unknown | imprecise | undetected | Insufficient^*^
Observational studies | None | - | - | - | - | - | Insufficient

AF = atrial fibrillation; KQ = Key Question; RCT = randomized controlled trial; RFA = radiofrequency ablation.

* Conclusions are not possible secondary to study limitations, small sample sizes resulting in low precision of estimates and/or limited data from single studies.

Table G6 Key findings and strength of evidence for Key Question 1: What is the comparative efficacy and effectiveness of AF catheter ablation on long- (>12 months) term outcomes in the general adult and Medicare populations? Consider (a) Comparison of energy sources: Cryoballoon ablation versus RFA

Long-term (>12 months) Efficacy, KQ 1a: Cryoballoon ablation versus RFA | Number of Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | SoE grade
Mortality (all cause) >30 days
Paroxysmal AF
Observational studies | 1 (N=396) | Medium | Direct | Unknown | imprecise | undetected | Insufficient^*^
Persistent AF, Mixed Population | None | - | - | - | - | - | Insufficient
Freedom From AF Recurrence
Paroxysmal AF | None | - | - | - | - | - | Insufficient
Observational studies | 2 (N=498) | Medium | Direct | consistent | imprecise | undetected | Insufficient^*^
Persistent AF, Mixed Population | None | - | - | - | - | - | Insufficient
Reablation
Paroxysmal AF, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed Population
Observational studies | 1 (N= 177) | Medium | Direct | Unknown | imprecise | undetected | Insufficient^*^

AF = atrial fibrillation; KQ = Key Question; RCT = randomized controlled trial; RFA = radiofrequency catheter ablation.

* Conclusions are not possible secondary to study limitations, small sample sizes resulting in low precision of estimates and/or limited data from single studies.

Table G7 Key findings and strength of evidence for KQ 2: What are the comparative short- and long-term complications and harms (e.g., periprocedural or device-related harms) associated with AF catheter ablation in the general adult and Medicare populations? Consider (a) Catheter ablation versus medical therapy: radiofrequency ablation (RFA) versus medical therapy

Safety, KQ 2a: RFA Versus Medical Therapy | Number of Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Grade
Mortality <30 days
All RCTs (regardless of AF type) | 5 (N = 761) | medium | direct | consistent | imprecise | undetected | Low
Paroxysmal AF
RCTs | 3 (N = 570) | medium | direct | consistent | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Persistent AF
RCTs | 2 (N = 191) | medium | direct | unknown | imprecise | undetected | Low
Observational (Medicare population) | 1 (N = 412) | low | direct | unknown | imprecise | undetected | Insufficient^*^
Stroke <30 days
All RCTs (regardless of AF type) | 8 (N = 919) | medium | direct | consistent | imprecise | undetected | Low
Paroxysmal AF
RCTs | 3 (N = 481) | medium | direct | consistent | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Persistent AF
RCTs | 2 (N = 181) | medium | direct | consistent | imprecise | undetected | Low
Observational (Medicare population) | 1 (N = 412) | low | direct | unknown | imprecise | undetected | Insufficient^*^
Mixed population
RCTs | 2 (N = 207) | medium | direct | consistent | imprecise | undetected | Low
Observational studies | 1 (N = 166) | high | direct | unknown | imprecise | undetected | Insufficient^*^
AF <3 months
Paroxysmal AF
RCTs | 2 (N = 183) | medium | direct | consistent | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Persistent AF
RCTs | 2 (N = 196) | medium | direct | consistent | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Mixed population
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 1 (N = 85) | high | direct | unknown | imprecise | suspected | Insufficient^*^
Cardiac Tamponade^†^
Paroxysmal AF
RCTs | 4 (N = 512) | medium | direct | consistent | imprecise | undetected | Low
Observational studies | 1 (N = 85) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Persistent AF
RCTs | 3 (N = 73) | medium | direct | consistent | imprecise | undetected | Insufficient^*^
Observational (Medicare population) | 1 (N = 158) | low | direct | unknown | imprecise | undetected | Insufficient^*^
Pericardial Effusion^†^
All RCTs (regardless of AF type) | 5 (N = 772) | medium | direct | consistent | imprecise | undetected | Low
Paroxysmal AF
RCTs | 3 (N = 519) | medium | direct | consistent | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Persistent AF
RCTs | 1 (N = 116) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Observational (Medicare population) | 1 (N = 158) | low | direct | unknown | imprecise | undetected | Insufficient^*^
Mixed population
RCTs | 1 (N = 137) | low | direct | unknown | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Pulmonary vein stenosis^†^
Paroxysmal AF
RCTs | 5 (N = 433) | medium | direct | consistent | imprecise | undetected | Low
Observational studies | 1 (N = 85) | | | | | | Insufficient^*^
Persistent AF
RCTs | 2 (N = 137) | medium | direct | consistent | imprecise | undetected | Low
Observational (Medicare population) | 1 (N = 158) | low | direct | unknown | imprecise | undetected | Insufficient^*^
Mixed population
RCTs | 1 (N = 137) | low | direct | unknown | imprecise | undetected | Low
Observational studies | 1 (N = 85) | | | | | | Insufficient^*^
Drug intolerance requiring discontinuation
Paroxysmal
RCTs | 2 (N = 155 medical therapy patients) | medium | direct | consistent | imprecise | undetected | Low
Observational studies | None | - | - | - | - | - | Insufficient
Persistent
RCTs | None | - | - | - | - | - | Insufficient
Observational (Medicare population) | 1 (N = 412) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Mixed population
RCTs | 1 (N = 70) | medium | direct | unknown | imprecise | undetected | Insufficient^*^
Observational studies | None | - | - | - | - | - | Insufficient

AF = atrial fibrillation; KQ = Key Question; RCT = randomized controlled trial; RFA = radiofrequency catheter ablation.

* Conclusions are not possible secondary to study limitations, small sample sizes or sparse data resulting in low precision of estimates, and/or unknown consistency from single studies.

† Ablation-related adverse events were reported for all patients who received ablation, either as randomized or who crossed over from the medical therapy group.

Table G8 Key findings and strength of evidence for Key Question 2: Comparative short-term and long-term complications and harms associated with cryoballoon ablation versus medical therapy for AF

Harms, KQ 2a (one RCT^*^): Cryoballoon ablation versus Medical Therapy | Number of studies^*^ (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | SoE grade
Mortality <30 days
Paroxysmal, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed population | 1 (N = 245) | medium | direct | unknown | imprecise | undetected | Insufficient^†^
Stroke <30 days
Paroxysmal, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed population | 1 (N = 245) | medium | direct | unknown | imprecise | undetected | Insufficient^†^
AF <3 months
Paroxysmal, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed population | 1 (N = 163) | medium | direct | unknown | imprecise | undetected | Insufficient^†^
Cardiac Tamponade^‡^
Paroxysmal, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed population | 1 (N = 228) | medium | direct | unknown | imprecise | undetected | Insufficient^†^
Pericardial Effusion^‡^
Paroxysmal, Persistent AF, mixed population | None | - | - | - | - | - | Insufficient
Pulmonary Vein Stenosis^‡^
Paroxysmal, Persistent AF | None | - | - | - | - | - | Insufficient
Mixed population | 1 (N = 228) | medium | direct | unknown | imprecise | undetected | Insufficient^†^
Drug intolerance requiring discontinuation
Paroxysmal, Persistent AF, Mixed population | None | - | - | - | - | - | Insufficient

AF = atrial fibrillation; KQ = Key Question; RCT = randomized controlled trial.

* Only 1 RCT (no observational studies) was identified for this comparison.

† Conclusions are not possible secondary to study limitations, small sample sizes or sparse data resulting in low precision of estimates, and/or unknown consistency from single studies.

‡ Ablation-related adverse events were reported for all patients who received ablation, either as randomized or who crossed over from the medical therapy group.

Table G9 Key findings and strength of evidence for KQ 2: What are the comparative short- and long-term complications and harms (e.g., periprocedural or device-related harms) associated with AF catheter ablation in the general adult and Medicare populations? Consider (b) Comparing ablation using different energy sources: Cryoballoon ablation versus radiofrequency ablation (RFA)

Safety, KQ 2b: Cryoballoon ablation Versus RFA | Number of Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Strength of Evidence Grade
Mortality <30 days
Paroxysmal AF
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 2 (N = 4171) | high | direct | consistent | precise | undetected | Insufficient^*^
Persistent AF, Mixed population | None | - | - | - | - | - | Insufficient
Stroke <30 days
All RCTs (regardless of AF type) | None | - | - | - | - | - | Insufficient
Paroxysmal AF
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 1 (N = 133) | low | direct | unknown | imprecise | undetected | Insufficient^*^
Persistent AF, Mixed population | None | - | - | - | - | - | Insufficient
AF <3 months
Paroxysmal AF
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 1 (N = 3775) | high | direct | unknown | precise | undetected | Insufficient^*^
Persistent AF, Mixed population | None | - | - | - | - | - | Insufficient
Cardiac Tamponade^†^
Paroxysmal AF
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 3 (N = 4304) | low | direct | unknown | imprecise | undetected | Insufficient^*^
Persistent AF, Mixed population | None | - | - | - | - | - | Insufficient
Pericardial Effusion^†^
Paroxysmal AF
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 2 (N = 529) | low | direct | unknown | imprecise | undetected | Insufficient^*^
Persistent AF | None | - | - | - | - | - | Insufficient
Mixed population
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 1 (N = 267) | high | direct | unknown | imprecise | undetected | Insufficient^*^
Pulmonary vein stenosis^†^
Paroxysmal AF
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 2 (N = 4171) | high | direct | consistent | precise | undetected | Insufficient
Persistent AF | None | - | - | - | - | - | Insufficient
Mixed population
RCTs | None | - | - | - | - | - | Insufficient
Observational studies | 1 (N = 124) | high | direct | unknown | imprecise | undetected | Insufficient^*^

AF = atrial fibrillation; KQ = Key Question; RCT = randomized controlled trial; RFA = radiofrequency catheter ablation.

* Conclusions are not possible secondary to study limitations, small sample sizes or sparse data resulting in low precision of estimates, and/or unknown consistency from single studies.

† Ablation-related adverse events were reported for all patients who received ablation, either as randomized or who crossed over from the medical therapy group.