# Quality Assessment of Included Studies

Table F1 Study Quality Ratings of Included RCTs Comparing Radiofrequency Catheter Ablation Versus Medical Therapy in Patients with Paroxysmal or Persistent Atrial Fibrillation

Methodological Principle | Forleo (2009)66 | Hunter (2014)61 | Jais (2008)55 | Jones (2013)65 | MacDonald (2011)62 | Mont (2014)63 | Morillo (2014)56 | Cosedis Nielsen (2012)54 | Oral (2006)64 | Pappone (2011/2006)57,58 | Stabile (2006)67 | Wazni (2005)59 | Wilber (2010)60
Study Design Randomized controlled trial Prospective cohort study Retrospective cohort study Case-control Case-series | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓
Random sequence generation^*^ | ✓ | ✓ | | ✓ | ✓ | | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓
Statement of concealed allocation^*^ | | | | | | | | | | | ✓
Intention to treat^*^ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓
Independent or blinded outcome assessment | | ✓ | | | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | | ✓
Patients blinded to treatment received
Attrition (≤ 20% overall; ≤ 10% difference between groups) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓
Controlling for possible confounding^†^ | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓
Full reporting on prespecified outcomes | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓
Overall Quality Rating | Fair | Fair | Fair | Fair | Fair | Fair | Fair | Fair | Fair | Fair | Good | Fair | Fair

* Applies only to randomized controlled trials

† Groups must be comparable on baseline characteristics or evidence of control for confounding presented

Blank cells indicate that the criterion was either not met or that it could not be determined

Table F2 Study Quality Ratings of Included Observational Studies Comparing Radiofrequency Catheter Ablation Versus Medical Therapy in Patients with Paroxysmal or Persistent Atrial Fibrillation

Methodological Principle | Blandino (2013)71 | Lan (2009)68 | Reynolds (2012)72 | Rossillo (2008)73 | Sang (2013)69 | Sonne (2009)74 | Yu (2012)70
Study Design Randomized controlled trial Prospective cohort study Retrospective cohort study Case-control Case-series | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓
Random sequence generation^*^
Statement of concealed allocation^*^
Intention to treat^*^
Independent or blinded outcome assessment
Patients blinded to treatment received
Attrition (≤ 20% overall; ≤ 10% difference between groups) | ✓ | | | | ✓ | | ✓
Controlling for possible confounding^†^ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓
Full reporting on prespecified outcomes | ✓ | ✓ | ✓ | ✓ | | | ✓
Overall Quality Rating | Fair | Fair | Fair | Poor | Fair | Poor | Poor

* Applies only to randomized controlled trials

† Groups must be comparable on baseline characteristics or evidence of control for confounding presented

Blank cells indicate that the criterion was either not met or that it could not be determined

Table F3 Study Quality Ratings of the Included RCT Comparing Cryoballoon Ablation with Medical Therapy with a Mixed Population of Patients with Atrial Fibrillation

Methodological Principle | Packer (2013)75
Study Design Randomized controlled trial Prospective cohort study Retrospective cohort study Case-control Case-series | ✓
Random sequence generation^*^
Statement of concealed allocation^*^
Intention to treat^*^ | ✓
Independent or blinded outcome assessment | ✓
Patients blinded to treatment received
Attrition (≤ 20% overall; ≤ 10% difference between groups) | ✓
Controlling for possible confounding^†^ | ✓
Full reporting on prespecified outcomes | ✓
Overall Quality Rating | Fair

* Applies only to randomized controlled trials

† Groups must be comparable on baseline characteristics or evidence of control for confounding presented

Blank cells indicate that the criterion was either not met or that it could not be determined

Table F4 Study Quality Ratings of Included RCTs Comparing Radiofrequency Catheter Ablation with Cryoballoon Ablation in Patients with Paroxysmal or Persistent Atrial Fibrillation

Methodological Principle | Herrera Siklody (2012)81 | Perez Castellano (2014)76
Study Design Randomized controlled trial Prospective cohort study Retrospective cohort study Case-control Case-series | ✓ | ✓
Random sequence generation^*^ | | ✓
Statement of concealed allocation^*^
Intention to treat^*^ | | ✓
Independent or blinded outcome assessment | | ✓
Patients blinded to treatment received
Attrition (≤ 20% overall; ≤ 10% difference between groups) | | ✓
Controlling for possible confounding^†^ | ✓ | ✓
Full reporting on prespecified outcomes | ✓ | ✓
Overall Quality Rating | Poor | Fair

* Applies only to randomized controlled trials

† Groups must be comparable on baseline characteristics or evidence of control for confounding presented

Blank cells indicate that the criterion was either not met or that it could not be determined

Table F5 Study Quality Ratings of Included Observational Studies Comparing Radiofrequency Catheter Ablation with Cryoballoon Ablation in Patients with Paroxysmal or Persistent Atrial Fibrillation

Methodological Principle | Chierchia (2010)77 | Mandell (2013)83 | Knecht (2014)78 | Kojodjojo (2010)82 | Mugnai (2014)79 | Schmidt (2014)80
Study Design Randomized controlled trial Prospective cohort study Retrospective cohort study Case-control Case-series | ✓ | ✓ | ✓ | ✓ | ✓ | ✓
Random sequence generation^*^
Statement of concealed allocation^*^
Intention to treat^*^
Independent or blinded outcome assessment
Patients blinded to treatment received
Attrition (≤ 20% overall; ≤ 10% difference between groups) | ✓ | ✓ | | | | ✓
Controlling for possible confounding^†^ | ✓ | | ✓ | | ✓
Full reporting on prespecified outcomes | ✓ | ✓ | ✓ | ✓
Overall Quality Rating | Fair | Poor | Fair | Poor | Poor | Poor

* Applies only to randomized controlled trials

† Groups must be comparable on baseline characteristics or evidence of control for confounding presented

Blank cells indicate that the criterion was either not met or that it could not be determined

Studies rated “good” will be considered to have the least risk of bias, and their results will be considered valid. Good-quality studies include clear descriptions of the population, setting, interventions, and comparison groups; a valid method for allocation of patients to treatment; low dropout rates and clear reporting of dropouts; appropriate means for preventing bias; and appropriate measurement of outcomes.

Studies rated “fair” will be susceptible to some bias, though not enough to invalidate the results. These studies may not meet all the criteria for a rating of good quality, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems. The fair-quality category is broad, and studies with this rating will vary in their strengths and weaknesses. The results of some fair-quality studies are likely to be valid, while others may be only possibly valid.

Studies rated “poor” will have significant flaws that imply biases of various types that may invalidate the results. They will have a serious or “fatal” flaw in design, analysis, or reporting; large amounts of missing information; discrepancies in reporting; or serious problems in the delivery of the intervention. The results of these studies will be least as likely to reflect flaws in the study design as the true difference between the compared interventions. We will not exclude studies rated as being poor in quality a priori, but poor-quality studies will be considered to be less reliable than higher quality studies when synthesizing the evidence, particularly if discrepancies between studies are present.