# Evidence Tables

Table E1 Demographics of Included RCTs Comparing Radiofrequency Catheter Ablation versus Medical Therapy in Patients with Paroxysmal Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Demographics | Patient Characteristics | Followup Blanking Period % Crossover | Interventions
Cosedis Nielsen, 2012^54^ Denmark, Finland, Sweden, Germany | - RCT; - Fair Quality; - Multicenter (# of sites NR); - AADs used only in medical treatment group; - 100% 1^st^ line therapy | N = 294 70.1% male Age = 55 years [underlined: RFA]: n = 146 68.5% male Age = 56 ± 9 years [underlined: Med]: n =148 71.6% male Age = 54 ± 10 years [underlined: Special Population]: No | [underlined: Left atrial diameter]:; - RFA: 40 ± 6 mm (echocardiography); - Med: 40 ± 5 mm (echocardiography); [underlined: AF Duration]: NR | [underlined: FU]: 93.5% (275/294); 3, 6, 12, 18, 24 mo [underlined: Blanking period]: 3 months [underlined: % Crossover]:; - RFA: n = 13 (9%); circumstances NR; timing NR ("by 24 months"); - Med: n = 54 (37%); if antiarrhythmic drug therapy failed (i.e. recurrent AF); first ablation procedure at a mean of 8.7 ± 6.5 months after inclusion in the study | [underlined: Ablation]:; - Circumferential PVI (%NR); - Roof of the atrium (%NR); - Cavotricuspid and mitral isthmuses (optional) (%NR); - AADs NR after the blanking period; [underlined: Medical Therapy]:; - Flecainide 200 mg/day or Propafenone 600 mg/day 89.7% (131/146); - Amiodarone 200 mg/day or Sotalol 160 mg/day 10.3% (15/146); [underlined: Mapping]:; - Electroanatomical mapping (CARTO, Biosense Webster)
Jais, 2008^55^ Canada, USA, France | - RCT; - Fair quality; - Multicenter (4 sites); - AADs used only in medical treatment group; - 100% 2^nd^ line therapy | N = 112 83.9% male Age = 51.1 years [underlined: RFA]: n = 53 84.9% male Age = 49.7 ± 10.7 years [underlined: Med]: n = 59 83.1% male Age = 52.4 ± 11.4 years [underlined: Special Population]: No | [underlined: Left atrial diameter]:; - RFA: 39.5 ± 5.6 mm (transthoracic echocardiography); - Med: 40.0 ± 5.7 mm (transthoracic echocardiography); - Total: 39.8 ± 5.6 mm (transthoracic echocardiography); [underlined: AF Duration]: (median and IQR); - RFA: 4.0 (1.0 – 12.0) hours; - Med: 6.0 (2.0 – 15.0) hours; - Total: 5.5 (1.0 – 12.0) hours | [underlined: FU]: 95.5% (107/112); 3, 6, 12 mo [underlined: Blanking period]: 90 days [underlined: % Crossover]:; - RFA: 9.4% (5/53); permitted after 3 months in case of failure (recurrent AF lasting >3 minutes and occurring after the stabilization period); - Med: 62.7% (37/59); permitted after 3 months in case of failure (recurrent AF lasting >3 minutes and occurring after the stabilization period) | [underlined: Ablation]:; - Left PVI 100% (53/53); - Right PVI 100% (53/53); - Right inferior vein isolation 100% (53/53); - Cavotricuspid isthmus 64.2% (34/53); - Roof of the left atrium 17% (9/53); - Mitral isthmus 30.2% (16/53); - Foci from nonvenous structures 22.6% (12/53); - AADs NR; [underlined: Medical Therapy (drugs administered either alone or in combination)]:; - Amiodarone (loading dose of 600 mg/d for 21 days followed by 200 mg/d was recommended, with an increase to 300 mg daily if required) (%NR); - Quinidine (%NR); - Disopyramide (%NR); - Flecainide (%NR); - Propafenone (%NR); - Cibenzoline (%NR); - Dofetilide (%NR); - Sotalol (%NR); [underlined: Mapping]:; - After transseptal access to the left atrium, isolation of all 4 pulmonary veins was performed using circumferential applications of radiofrequency energy and verified with a circular mapping catheter (Lasso Catheter, Biosense Webster, Inc, Diamond Bar, Calif)
Morillo (2014)56 USA, Canada, Germany, Czech Republic, Italy | - RCT; - Fair quality; - Multicenter (16 sites); - AADs used only in medical treatment group; - 100% 1^st^ line therapy | N = 127 75.6% male Age = 53.3 years [underlined: RFA]: n = 66 77.3% male Age = 56.3 ± 9.3 years [underlined: Med]: n = 61 73.8% male Age = 54.3 ± 11.7 years [underlined: Special Population]: No | [underlined: Left atrial diameter]:; - RFA: 40 mm ± 5 mm (mode NR); - Med: 43 cm ± 5 mm (mode NR); [underlined: AF Duration]:; - RFA: 47.4 ± 97.9 (IQR: 5.0 – 40.0) episodes in the past 6 months; - Med: 33.0 ± 48.7 (IQR: 4.0 – 40.0) episodes in the past 6 months | [underlined: FU]: 82.7% (105/127); 12, 24 mo [underlined: Blanking period]; 90 days [underlined: % Crossover]:; - RFA: 9.1% (6/66), circumstances NR; - Med: 42.6% (26/61); If treatment had failed, defined as drug discontinuation due to intolerance, adverse events, or inefficacy (i.e. recurrence of documented AF or any atrial tachyarrhythmias lasting >30 seconds) | [underlined: Ablation]:; - Circumferential PVI 98.5% (65/66); - PVI + cavotricuspid isthmus (%NR); - PVI + CFAE (%NR); - PVI+ roof line (%NR); - Beta-blockers 60.6% (at baseline); - Calcium channel blockers 21.2% (at baseline); - AADs NR; [underlined: Medical Therapy]:; - Flecainide 175.8 ± 50.9 mg/d; 69%; - Propafenone 487.7 ± 122.4 mg/d; 25%; - Beta-blockers 59% (at baseline); - Calcium channel blockers 21.3% (at baseline); [underlined: Mapping]:; - Nonfluroscopic mapping systems were used in 86% of patients
Pappone (2006)57 Italy | - RCT; - Fair Quality; - Single center; - AADs used only in medical treatment group; - 100% 2^nd^ line therapy | N = 198 67.2% male Age = 56 years [underlined: RFA]: n = 99 69.7% male Age = 55 ± 10 years [underlined: Med]: n = 99 64.6% male Age = 57 ± 10 years [underlined: Special Population]: No | [underlined: Left atrial diameter]:; - RFA: 40 ± 6 mm (mode NR); - Med: 38 ± 6 mm (mode NR); [underlined: AF Duration]:; - RFA: 6 ± 4 (episodes/ mo); 6 ± 4 years; - Med: 6 ± 6 (episodes/ mo); 6 ± 6 years; - Total: 3.4 (episodes/ mo); 6 ± 5 years | [underlined: FU]: 100% (198/198); 12 mo [underlined: Blanking period:] 6 weeks [underlined: % Crossover:]; - RFA: 5/99 (5.1%) Recurrence of symptomatic AF (documented by transtelephonic ECG monitoring), crossover > 6 weeks after first ablation (80% (4/5) flecainide; 20% (1/5) sotalol); - Med: 42/99 (42.4%) Recurrence of symptomatic or asymptomatic AF (documented by transtelephonic ECG monitoring), after 2 trials of medical therapy, patients could be considered for crossover to ablation (> 3 months after blanking period). | [underlined: Ablation]:; - Circumferential PVI 100% (99/99); - PVI + cavotricuspid isthmus 100% (99/99); - AAD usage NR; [underlined: Medical Therapy]:; - Amiodarone, initial loading dose: 600 mg/day for the first week, 400 mg/day in the second week, then maintenance dose 200 mg/day, (single drug: 54.1% (33/61), in combination: 45.9% (28/61)); - Flecainide, initial dose: 100 mg/12 hrs (%NR); - Sotalol, initial dose: 80 mg/8 hrs (%NR);; [underlined: Mapping]:; - CARTO (Biosense-Webster, Diamond Bar, California); - NavX (Endocardial Solutions Inc., St. Paul, Minnesota)
Pappone (2011)58 Italy | - RCT; - Fair Quality; - Single Center; - AADs used only in medical treatment group; - 100% 2^nd^ line therapy | N = 198 67.2% male Age = 56 years [underlined: RFA]: n = 99 69.7% male Age = 55 ± 10 years [underlined: Med]: n = 99 64.6% male Age = 57 ± 10 years [underlined: Special Population]: No | [underlined: Left atrial diameter]:; - RFA: 40 ± 6 mm (mode NR); - Med: 38 ± 6 mm (mode NR); [underlined: AF Duration:]; - RFA: 6 ± 4 years; - Med: 6 ± 6 years | [underlined: FU]: 95% (188/198); 4 years [underlined: Blanking Period]: 6 weeks [underlined: % Crossover:]; - RFA: NR; - Med: 87/99 (87.9%) by 4 years f/u; After intolerance, serious side effects, or failure of AADs in different classes and/or combination or after symptomatic and sustained episodes of arrhythmia recurrences ( > 12 hours) | [underlined: Ablation]:; - PVI + mitral isthmus and between contralateral superior veins (%NR); - AADs NR; [underlined: Medical Therapy]:; - Flecainide (initial dosage of 100 mg every 12 hours, maximum tolerable dosage 300mg/day);; - Sotalol (initial dose of 80 mg every 8 hours, maximum tolerable dosage 320 mg/day); - Amiodarone (initial loading of 600 mg/d for the first week, 400 mg/d for the next week, after which a daily maintenance dose of 200 mg a day was given); [underlined: Mapping]:; - 3D-electoanatomic mapping systems (CARTO (Biosense-Webster, Diamond Bar, California); - NavX (Endocardial Solutions Inc., St. Paul, Minnesota))
Wazni (2005)59 Italy & Germany | - RCT; - Fair Quality; - Multicenter (3 sites; - AADs used only in medical treatment group; - 100% 1^st^ line therapy | N = 70 % male NR Age = 53.5 years [underlined: RFA]: n = 33 % male NR Age = 53 ± 8 years [underlined: Med]: n =37 % male NR Age = 54 ± 8 years [underlined: Special Population]: No | [underlined: Left atrial diameter]:; - RFA: 41 ± 8 mm (mode NR); - Med: 42 ± 7 mm (mode NR); [underlined: AF Duration]:; - RFA:5 ± 2 months; - Med: 5 ± 2.5 months | [underlined: FU]: 67/70 (95.7%); 6, 12 mo [underlined: Blanking period]: Initial 2 mo after enrollment [underlined: % Crossover]:; - RFA: after 1 year, 3.1%(1/32) started antiarrhythmic drugs to maintain sinus rhythm; - Med: after 1 year, 51.4% (18/35) patients underwent ablation because of recurrent AF | [underlined: Ablation]:; - PVI of all 4 veins 100% (33/33); - AADs NR; [underlined: Medical Therapy]:; - Flecainide (100–150mg twice per day); - Propafenone (225–300mg three times per day); - Sotalol (120–160mg twice per day); [underlined: Mapping]:; - Multipolar mapping catheter to record right atrial and coronary sinus electrocardiograms
Wilber (2010)60 USA, Canada, “Latin America”, Europe (NR) | - RCT; - Fair Quality; - Multicenter (9 sites); - AADs used only in medical treatment group; - 100% 2^nd^ line therapy | N = 158 66.5% male Age = 55.7 [underlined: RFA]: n = 103 68.9% male Age = 55.5 (95% CI: 53.7–57.3) years [underlined: Med]: n = 56 62.3% male Age = 56.1 (95% CI: 52.9–59.4) years [underlined: Special Population:] No | [underlined: Left atrial diameter]:; - RFA: mean (SD) 40.0 (38.9–41.1) mm (mode NR); - Med: mean (SD) 40.5 (39.0–41.9) mm (mode NR); [underlined: AF Duration]:; - RFA: median (IQR) 5.4 (4.3–6.5) years; - Med: median (IQR) 6.2 (4.6–7.9) years | [underlined: FU]: NR; 3, 12 mo [underlined: Blanking Period]: RFA: 3 months Med: 14 days [underlined: % Crossover]:; - RFA: n = 5; circumstances NR; - Med: n = 36 (mean time 3.9 (95% CI, 3.1–4.6) months from the onset of the effectiveness evaluation period); after 90 days of therapy if the treatment failed | [underlined: Ablation]:; - PVI 100% (103/103); - PVI + cavotricuspid isthmus 35.9% (37/103); - PVI + superior vena cava 16.5% (17/103); - PVI + other left/ right atrial foci 16.5% (17/103); - PVI + at least 1 left atrial linear lesion (including mitral isthmus and roof lines) 22.3% (23/103); - Use of AADs NR; [underlined: Medical Therapy]:; - Flecainide 36% (20/56); - Propafenone 41% (23/56); - Sotalol 20% (11/56); - Dofetilide 4% (2/56); - Dosages NR; [underlined: Mapping]:; - Carto Navigation System (Biosense Webster)

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; CFAE = Complex fractionated atrial electrograms; CI = Confidence Interval; ECG = Electrocardiography; FU = Followup; IQR = Interquartile range; NR = Not reported; PVI = Pulmonary Vein Isolation; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SD = Standard deviation.

Table E2 Demographics of Included RCTs Comparing Radiofrequency Catheter Ablation versus Medical Therapy in Patients with Persistent Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Demographics | Patient Characteristics | Followup Blanking Period % Crossover | Interventions
Hunter (2014)61 | - RCT (CAMTAF Trial); - Fair quality; - Single center; - AADs used in both treatment groups; - 100% 1^st^ line therapy | N = 50 96% male Age = 57.4 years [underlined: RFA:] n = 26 96.1% male Age = 55 ± 12 years [underlined: Med:] n = 24 95.8% male Age = 60 ± 10 years [underlined: Special Population:] Yes, 100% patients have had heart failure | [underlined: Left atrial diameter:]; - RFA: 5.2 ± 1.1 cm (mode NR); - Med: 5.0 ± 1.0 cm (mode NR); [underlined: AF Duration:]; - RFA: 24 (17 – 33) months (median, IQR); - Med: 24 (12 – 48) months (median, IQR) | [underlined: FU:] 96% (48/50); 6 mo, ablation only 12 mo [underlined: Blanking period:] RFA: 3 mo Med: NR [underlined: % Crossover:] NR | [underlined: Ablation:]; - Pulmonary veins isolated by wide area circumferential ablation, with lesions placed 1 to 2 cm outside pulmonary vein to isolate them as ipsilateral pairs 96.1% (25/26); - Linear lesions added at mitral isthmus and roof if patients remained in AF (%NR); - Cavotricuspid isthmus line added only in patients with history of typical right atrial flutter (%NR); - If AF organized into atrial tachycardia, was mapped and ablated (%NR); - If sinus rhythm not restored following these lesions, patient was cardioverted with DC shock (%NR); - Heparin (dose NR) 96.1% (25/26); - AADs (type, dose NR) not stopped during procedure 96.1% (25/26); - Same “baseline” drugs as medical therapy 96.1%(25/26); [underlined: Medical Therapy:]; - Beta-blockers, angiotensin-converting enzyme inhibitors, or angiotensin receptor blockers (dose NR) 92% (23/24); - Spironolactone (if NYHA class ≥ III and LV EF < 35%), some patients (%NR); - Warfarin with a target international normalized ration of 2 – 3 (dose NR) 92% (23/24); [underlined: Mapping:]; - 3-dimensional mapping system either Carto (Biosense Webster Inc, Diamond Bar, CA) or Ensite NavX (St Jude Medical, Minneapolis, MN), with computerized tomography or MRI image integration
MacDonald (2011)62 Scotland | - RCT; - Fair Quality; - Multicenter (6 sites); - AADs used in both treatment groups; - 100% 1^st^ line therapy | N = 41 78% male Age = 63.3 years [underlined: RFA]: n = 22 77% male Age = 62.3 ± 6.7 years [underlined: Med]: n = 19 79% male Age = 64.4 ± 8.3 years [underlined: Special Population]: Yes, 100% patients have had heart failure | [underlined: Left atrial diameter]:; - RFA: NR; - Med: NR; [underlined: AF Duration]:; - RFA: 44 ± 36.5 months; - Med: 64 ± 47.6 months | [underlined: FU]: 92.7% (38/41); 6 mo [underlined: Blanking period]: RFA: 3 mo Med: NR [underlined: % Crossover]: NR | [underlined: Ablation]:; - Electrical isolation of all four pulmonary veins, with an additional adjoining roof line and further ablation at sites of CFAEs 100% (21/21); - Additional atrial flutter ablation 9.5% (2/21); - Amiodarone (dosage NR) 100% (21/21); - Same “baseline” drugs as medical therapy; [underlined: Medical Therapy]:; - Digoxin (dosage NR) (number of patients who received drug for heart rate > 80 bpm, NR); - Baseline:; - Digoxin (dosage NR) 47% (9/19); - Aldosterone antagonist (dosage NR) 16% (3/19); - Beta blocker (dosage NR) 95% (18/19); - Angiotensin-converting enzyme or angiotensin II receptor blocker (dosage NR) 95% (18/19); [underlined: Mapping]:; - Pulmonary vein and left atrial anatomy was delineated with pulmonary venous angiography and three-dimensional reconstruction of the left atrium using Nav-X mapping system (St Jude Medical, Minnesota, USA); - Pulmonary vein recordings were performed with a duodecapolar variable-diameter circular mapping catheter (Lasso (Biosense Webster, California, USA) or Inquiry Optima (St Jude Medical))
Mont (2014)63 Spain | - RCT; - Fair Quality; - Multicenter (8 sites); - AADs used in both treatment groups; - 100% 2^nd^ line therapy | N = 146 77.4% male Age = 55 years [underlined: RFA]: n = 93 77.5% male Age = 55 ± 9 years [underlined: Med]: n = 48 77.0% male Age = 55 ± 9 years [underlined: Special Population]: No | [underlined: Left atrial diameter]:; - RFA: 41.3 ± 4.6 mm (electroanatomic mapping system (CARTO)); - Med: 42.7 ± 5.1 mm (electroanatomic mapping system (CARTO)); [underlined: AF Duration]:; - RFA: NR; - Med: NR | [underlined: FU]: 98% (143/146); 6, 12 mo [underlined: Blanking Period]: 3 mo [underlined: % Crossover]:; - RFA: 35.7% (35/98), to relieve symptoms of paroxysmal AF or undocumented palpitations; crossovers considered those patients who received medical therapy BEFORE reaching the primary endpoint (12 months); - Med: 0/48 (0%); 23 patients (47.9%) underwent ablation AFTER reaching the primary endpoint (12 months) | [underlined: Ablation]:; - PVI 100% (93/93); - PVI + cavotricuspid isthmus 2% (2/93); - PVI + mitral isthmus line 3.1% (3/93); - PVI+ roof line 23.4% (23/93); - PVI + CFAE 8.1% (8/93); - All patients received AADs (Amiodarone, “class Ic, or another class III drug”); [underlined: Medical Therapy]:; - Amiodarone; - Flecainide plus diltiazem or beta-blockers; [underlined: Mapping]:; - A 3D map was constructed using an electroanatomic mapping system (CARTO, Biosense Webster, Diamond Bar, CA, USA or NAVX, St Jude Corporation, St Paul, MN, USA)
Oral (2006)64 USA, Italy | - RCT; - Multicenter (2 sites); - AADs used only in medical treatment group; - 100% 2^nd^ line therapy | N = 146 88% male Age = 56.4 years [underlined: RFA]: n = 77 87% male Age = 55 ± 9 years [underlined: Med Tx]: n = 69 90% male Age = 58 ± 8 years [underlined: Special Population]: No | [underlined: Left atrial diameter]:; - RFA: 45 ± 6 mm (mode NR); - Med: 45 ± 5 (mode NR); [underlined: AF Duration]:; - RFA: 5 ± 4 years; - Med Tx: 4 ± 4 years | [underlined: FU]: 100% (146/146), 12 months [underlined: Blanking Period]: NR [underlined: % Crossover]:; - RFA: 0% (0/77) withdrew consent; - Med Tx: 77% (53/69) crossed over a mean of 128 ± 57 days after the first cardioversion n | [underlined: Ablation]:; - PVI: 100% (77/77); - PVI + cavotricuspid isthmus: 71% (55/77)
Jones (2013)65 UK | - RCT; - Fair Quality; - Multicenter (2 sites); - AADs used only in medical treatment group; - Both 1^st^ and 2^nd^ line therapy | N = 52 87% male Age = 63 [underlined: RFA]: n = 26 81% male Age = 64 ± 10 years [underlined: Med]: n = 26 92% male Age = 62 ± 9 years [underlined: Special Population]: 100% of patients have had heart failure | [underlined: Left atrial diameter]:; - RFA: 50 ± 6 mm (m-mode); - Med: 46 ± 7 mm (m-mode); [underlined: AF Duration]:; - RFA: 51 ± 39 months (time since AF dx); 23 ± 22 months (duration of continuous AF); - Med: 51 ± 76 months (time since AF dx); 24 ± 29 months (duration of continuous AF) | [underlined: FU]: 96% (50/52); 3, 6, 12 months [underlined: Blanking period]: RFA: 2 months Med: none [underlined: % Crossover]:; - RFA: circumstances NR; 1 w/drew consent and continued existing therapy; - Med: circumstances NR; 1 had ablation at 4 mos | [underlined: Ablation (performed in a stepwise manner)]:; - PVI (%NR); - Linear ablation to the left atrial roof and mitral isthmus (%NR); - Left atrial CFAE (%NR); - No AADs after blanking period; [underlined: Medical therapy]:; - Beta-blockers and/ or digoxin (dosage NR); goal was mean HR ≤80 bpm resting and ≤110 bpm after 6 minute walk; [underlined: Mapping]:; - NavX mapping system with an AFoucsII catheter (St. Jude Medical)

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; CFAE = Complex fractionated atrial electrograms; CI = Confidence Interval; ECG = Electrocardiography; FU = Followup; IQR = Interquartile range; NR = Not reported; PVI = Pulmonary Vein Isolation; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SD = Standard deviation.

Table E3 Demographics of Included RCTs Comparing Radiofrequency Catheter Ablation versus Medical Therapy in Patients with Paroxysmal or Persistent Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Demographics | Patient Characteristics | Followup Blanking Period % Crossover | Interventions
Forleo (2009)66 Italy | - RCT; - Fair Quality; - Multicenter (3 sites); - AADs used only in medical treatment group; - 100% 2^nd^ line therapy | N = 70 61% male Age = 64 [underlined: RFA]: n = 35 57.1% male Age = 63.2 ± 8.6 [underlined: Med]: n = 35 65.7% male Age = 64.8 ± 6.5 [underlined: Special Population]: Yes, 100% of patients have diabetes | [underlined: AF Duration]:; - RFA: 41 (18–66) months (median, IQR); - Med: 36 (17–55) months (median, IQR); [underlined: Left atrial diameter]:; - RFA: 44.3 ± 5.6 mm (mode NR); - Med: 45.2 ± 5.2 mm (mode NR) | [underlined: FU]: 100% (70/70); 2, 4, 6, 8, 10, 12 months [underlined: Blanking Period]: 5 weeks [underlined: % Crossover]: Not permitted | [underlined: Ablation]:; - Circumferential PVI 100% (35/35); - Bidirectional cavotricuspid isthmus block 100% (35/35); - Mitral isthmus 23% (8/35); - Roofline ablation 9% (3/35); - AADs NR; [underlined: Medical Therapy]; - Class IC 77% (27/35); - Sotalol 9% (3/35); - Amiodarone 63% (22/35); - Calcium channel antagonist (details NR) 17% (6/35); [underlined: Mapping]:; - Nonfluoroscopic mapping (NavX mapping system (Endocaridal Solution Inc.) with the CARTO system (Biosense Webster))
Stabile (2006)67 Italy | - RCT; - Good Quality; - Multicenter (# of sites NR); - AADs used in both treatment groups; - 100% 2^nd^ line therapy | N = 137 59.1% male Age = 62.3 years [underlined: RFA]: n = 68 54.4% male Age = 62.2 ± 9 years [underlined: Med]: n = 69 63.8% male Age = 62.3 ± 10 years [underlined: Special Population]: No | [underlined: Left atrial diameter]; - RFA: 46 ± 5 mm (mode NR); - Med: 45.4 ± 5.5 mm (mode NR); [underlined: AF Duration]; - RFA: 5.1 ± 3.9 years; - Med: 7.1 ± 5.9 years | [underlined: FU]: 97.1% (133/137); 13 mo [underlined: Blanking Period]: 1 month % [underlined: Crossover]:; - RFA: NR; - Med: 57.1% (36/63) AF relapses 3 months after AF recurrence | [underlined: Ablation]:; - PVI + mitral isthmus, cavo-tricuspid isthmus, and circumferential PV ablation 100% (68/68), of these patients 13 patients had already undergone cavo-tricuspid ablations, only 55 of those procedures were completed during these trials; - All patients received AADs (see medical therapy); [underlined: Medical Therapy]:; - Amiodarone 209 ± 49 mg; - Flecainide 191 ± 28 mg; - Propafenone 750 ± 126 mg; - Sotalol 184 ± 54 mg; - Disopyramide (dosage NR); - Ace-inhibitors or angiotensin receptor blockers (dosage NR); - Verapamil or diltiazem (dosage NR); - Beta blockers (dosage NR); - Statins (dosage NR); [underlined: Mapping]:; - Real-time 3D left atrium maps were reconstructed using a nonfluoroscopic navigation system (CARTO, Biosense-Webster Inc., Diamond Bar, California). Maps were acquired during pacing from the coronary sinus

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; CFAE = Complex fractionated atrial electrograms; CI = Confidence Interval; ECG = Electrocardiography; FU = Followup; IQR = Interquartile range; NR = Not reported; PVI = Pulmonary Vein Isolation; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SD = Standard deviation.

Table E4 Demographics of Included Observational Studies Comparing Radiofrequency Catheter Ablation versus Medical Therapy in Patients with Paroxysmal Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Demographics | Patient Characteristics | Followup Blanking Period % Crossover | Interventions
Lan (2009)68,* China | - Prospective, comparative observational; - Fair quality; - Single center; - AADs used only in medical treatment; - 100% 2^nd^ line therapy | N = 240 65% male Age = 59.0 years [underlined: RFA]: n = 120 66% male Age = 59.5 years [underlined: Med]: n = 120 64% male Age = 58.5 years [underlined: Special Population]: No | [underlined: Left atrial diameter]:; - RFA: 34.66 mm (transthoracic echocardiogram; LA anteroposterior diameter was measured at end-systole on the M-mode image obtained from the parasternal long-axis view); - Med: 34.69 mm (transthoracic echocardiogram; LA anteroposterior diameter was measured at end-systole on the M-mode image obtained from the parasternal long-axis view); [underlined: AF Duration]: RFA: 2.63 years Med: 2.61 years | [underlined: FU]: %NR (n’s NR); 3, 6, 9, 12 mo [underlined: Blanking period]: 1 month % [underlined: Crossover]: NR | [underlined: Ablation]:; - CPVA 50% (60/120); - SPVI 50% (60/120); [underlined: Medical Therapy]:; - Amiodarone (60/120), dosage 600 mg day for the first week, 400 mg day for the second week and 200 mg day thereafter; - Amiodarone (same dosage as above) + losartan (60/120), 50 mg day for the first 2 weeks, See article for more dosage details; [underlined: Mapping]:; - NR
Sang (2013)69 China | - Prospective, comparative observational; - Fair quality; - Single center; - AADs used in both treatment groups; - 100% 2^nd^ line therapy | N = 175 68.1% male Age = 56.6 years [underlined: RFA]: n = 85 67.1% male Age = 55.9 ± 6.1 years [underlined: Med]: n = 90 69.1% male Age = 57.2 ± 5.4 years [underlined: Special Population]: LVEF <35% | [underlined: Left atrial diameter]: RFA: 39.0 ± 5.9 mm (mode NR) Med: 38.6 ± 6.2 mm (mode NR) [underlined: AF duration]: RFA: 90.1 ± 90.1 months Med: 86.9 ± 90.8 months | [underlined: FU]: 94.9% (166/175); 3, 6, 9, 12 mo [underlined: Blanking Period]: RFA: 3 months Med: NR [underlined: % Crossover]: NR | [underlined: Ablation]:; - Modified Brockenbrough technique; Circumferential isolation of the right pulmonary vein (PV) antrum (PVA) was performed first, followed by isolation of the left PVA (%NR); - If there were neither contraindications nor intolerance, patients would receive AADs for 2 months after ablation and then discontinue them if no AF recurred, dosage NR, Prior to ablation all AADs except for amiodarone were discontinued in patients for ≥5 half-lives; [underlined: Medical Therapy]:; - Amiodarone 60.7% (51/84); - Propafenone 38.1% (32/84); - Sotalol 19% (16.84); - ≥2 AADs 16.7% (14/84); - Dosage NR; [underlined: Mapping]:; - Catheter guided by electroanatomic mapping system (CARTO XP, Biosense-Webster), PV isolation was sometimes confirmed with a circular mapping catheter (Lasso; Biosense-Webster)
Yu (2012)70 China | - Retrospective, comparative observational; - Poor quality; - Single center; - AADs used in both treatment groups; - 100% 2^nd^ line therapy | N = 210 50.8% male Age = 55 years [underlined: RFA]: n = 98 50% male Age = 55.2 ± 6.5 years [underlined: Med]: n = 112 52% male Age = 54.9 ± 7 years [underlined: Special Population]: None | [underlined: Left atrial diameter]: RFA: 31.7 ± 1.9 mm (echocardiography) Med: 32 ± mm (echocardiography) [underlined: AF duration]: RFA: 2.4 ± 0.1 years Med: 2.3 ± 0.1 years | [underlined: FU]: 94.8% (199/210); 12 months [underlined: Blanking period]: RFA: 3 months Med: NR [underlined: % Crossover]: NR | [underlined: Ablation]; - Circumferential PVI 100% (97/97); - All patients were discharged on previously ineffective AADs, and stopped after a blanking period of 3 months; - Beta-blocker 27.8% (24/97); - Amiodarone 86% (84/97); - ACEI 81.4% (79/97); - ARB 8.3% (8/97); [underlined: Medical Therapy]; - Beta-blocker 29.4% (30/102); - Amiodarone 89.2% (91/102); - ACEI 81.4% (83/102); - ARB 10.8% (11/102); - Digitalis 2% (2/102); [underlined: Mapping]; - 3D left atrial maps and pulmonary vein profiles were reconstructed through a transseptal route using a nonfluoroscopic electrogeometric mapping system (CARTO, Biosense-Webster, Diamond Bar, CA, USA)

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; AMIO = amiodarone; CFAE = Complex fractionated atrial electrograms; CI = Confidence Interval; CPVA = circumferential pulmonary vein ablation; ECG = Electrocardiography; FU = Followup; IQR = Interquartile range; LO = losartan; NR = Not reported; PVI = Pulmonary Vein Isolation; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SD = Standard deviation; SPVI = segmental pulmonary vein isolation.

* Lan 2009: Age, AF duration, LA size, were calculated using a weighted mean of the two subgroups of each treatment group.

Table E5 Demographics of Included Observational Studies Comparing Radiofrequency Catheter Ablation versus Medical Therapy in Patients with Persistent Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Demographics | Patient Characteristics | Followup Blanking Period % Crossover | Interventions
Blandino (2013)71 Italy | - Prospective, comparative observational; - Fair quality; - Number of centers NR; - AADs used in both treatment groups; - 100% 2^nd^ line therapy | N = 412 72% male Age = 75.6 years [underlined: RFA]: n = 153 71% male Age = 75 ± 5 years [underlined: Med]: n = 259 72% male Age = 76 ± 6 years [underlined: Special Population]: Medicare population | [underlined: Left Atrial diameter]: RFA: 47 ± 5 mm (Doppler transthoracic echocardiography (TTE)) Med: 47 ± 6 mm (Doppler transthoracic echocardiography (TTE)) [underlined: AF Duration]: RFA: 6 ± 4 months Med: 6 ±4 months | [underlined: FU]: 100% (412/412); patients followed every 6 months after 12 month FU Mean: 60 ± 17 months [underlined: Blanking period]: RFA: “for group A patients, a 3-month blanking period was considered” Med: NR [underlined: % Crossover]: RFA: AF/AT recurrence; rate control approach 5.9% (9/153), ECV and continuation of previous AAD therapy 3.3% (5/153) Med: AF/AT recurrence; 1.9% (5/259) | [underlined: Ablation]; - PVI + cavotricuspid isthmus100% (153/153); - Linear lesions interconnecting the upper PV ostia (roof line) and the left inferior PV with the mitral annulus (left isthmus line) 60% (92/153); only performed in cases of AF persistence despite PVI; - AADs at the beginning of FU (patients continued the same regimen received before the procedure for at least 3 months):; - Amiodarone 42% (64/153); dosage: 194 ± 42 mg; - Flecainide 23% (35/153); dosage: 226 ± 20 mg; - Propafenone 14% (22/153); dosage: 638 ± 125 mg; - Sotalol 21% (32/153); dosage: 167 ± 32 mg; [underlined: Medical Therapy]^*^; - Amiodarone 45% (117/259); dosage: 233 ± 74 mg; - Flecainide 22% (57/153); dosage: 253 ± 38 mg; - Propafenone 21% (31/256); dosage: 665 ± 73 mg; - Sotalol 21% (54/259); dosage: 194 ± 47 mg; [underlined: Mapping]; - 3D reconstruction of the left atrium was performed using the electroanatomic mapping system (Carto, Biosense Webster)

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; AMIO = amiodarone; CFAE = Complex fractionated atrial electrograms; CI = Confidence Interval; CPVA = circumferential pulmonary vein ablation; ECG = Electrocardiography; FU = Followup; IQR = Interquartile range; LO = losartan; NR = Not reported; PVI = Pulmonary Vein Isolation; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SD = Standard deviation; SPVI = segmental pulmonary vein isolation.

* Blandino: in patients without heart disease and severe left ventricular hypertrophy, IC class AAD were the first choice. In patients with coronary heart disease and normal left ventricular ejection fraction (LVEF), sotalol was preferred; in patients with severe LV hypertrophy or heart failure amiodarone was the preferred drug. No specific regimen was established, although physicians were encouraged to comply with published guidelines. When amiodarone was prescribed, a loading dose of 600 mg/d for 21 days followed by 200 mg/d was recommended.

Table E6 Demographics of Included Observational Studies Comparing Radiofrequency Catheter Ablation versus Medical Therapy in Patients with Paroxysmal or Persistent Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Demographics | Patient Characteristics | Followup Blanking Period % Crossover | Interventions
Reynolds (2012)72 | - Retrospective comparative observational; - From matched cohort administrative database (MarketScan Research Database, Thomson Reuters); - AF type NR; - 100% 2^nd^ line | N = 1602 61.7% male Age = ≥65 yrs: 48.2 (386) [underlined: RFA]: n = 801 60.9% male Age = NR [underlined: Med]: n = 801 62.5% male Age = NR [underlined: Special Population]: No | [underlined: Left atrial diameter]: NR [underlined: AF Duration]: NR | [underlined: FU]: 100%; 27 mo (mean) [underlined: Blanking period]: NR [underlined: % Crossover]: NR | [underlined: Ablation]:; - PVI + superior vena cava 100% (85/85); [underlined: Medical Therapy]:; - Rate control medications such as beta-blockers, nondihydropyridine calcium channel blockers, and digoxin (%NR); - AADs 100%; - Warfarin (%NR); [underlined: Mapping]: NR
Rossillo (2008)73 Italy | - Retrospective, comparative observational; - Poor quality; - Single center; - AADs used only in medical treatment; - 2^nd^ line therapy for RFA group, NR for Med group | N = 170 84.7% male Age = 62 years [underlined: RFA]: n = 85 84% male Age = 62 ± 7.6 years [underlined: Med]: n = 85 84% male Age = 62 ± 7.6 years [underlined: Special Population]: No | [underlined: Left atrial diameter]: RFA: 44 ± 6 mm (mode NR) Med: 42 ± 7 mm (mode NR) [underlined: AF Duration]: RFA: 8 years, range (1–24) Med: NR | [underlined: FU]: %Nr (n’s NR); 3 mo Mean: 16 ± 7 mo [underlined: Blanking period]: RFA: 8 weeks Med: NR [underlined: % Crossover]: NR | [underlined: Ablation]:; - PVI + superior vena cavae 100% (85/85); - No AADs used unless recurrence developed; [underlined: Medical Therapy]:; - “All patients were pretreated with antiarrhythmic drug therapy to avoid early recurrences of atrial arrhythmias after electrical cardioversion”; [underlined: Mapping]:; - Mapping of the left atrium and pulmonary veins was carried out after approaching the left atrium via transseptal puncture
Sonne (2009)74 USA | - Retrospective, comparative observational; - Poor Quality; - AADs used in both treatment groups; - 100% 2^nd^ line therapy | N = 351 68.4% male Age = years [underlined: RFA]: n = 146 67.8% male Age = 67.2 ± 8 years [underlined: Med]: n = 205 68.8% male Age = 66.7 ± 7.7 years [underlined: Special Population]: Medicare population | [underlined: Left atrial diameter]: RFA:55 ± 8.7 (echocardiography) Med: 56 ± 8.7 (echocardiography) [underlined: AF Duration]: NR | [underlined: FU]: 89.4% (314/351) Mean: 69 ± 27 mo [underlined: Blanking period]: NR [underlined: % Crossover]: Crossover not permitted | [underlined: Ablation]; - Pulmonary vein antrum isolation 100% (146/146); - Beta-blocker 32% (46/146); - Calcium channel blocker 18% (27/146); - ACE-inhibitor/ARB (7% (40/146); - Digoxin 13% (19/146); - Amiodarone 3% (4/146); - Sotalol 10% (15/146); - Dofetilide 8% (11/146); - Flecainide 4% (5/146); - Propafenone 3% (4/146); - Other AADs 3% (5/146); - Dosages NR; [underlined: Medical Therapy]; - Beta-blocker 32% (65/205); - Calcium channel blocker 6% (12/205); - ACE-inhibitor/ARB 21% (43/205); - Digoxin 16% (33/205); - Amiodarone 14% (29/205); - Sotalol 6% (13/205); - Dofetilide 1% (3/205); - Flecainide 3% (6/205); - Propafenone 1% (3/205); - Other AADs 0.4% (1/205); - Dosages NR; [underlined: Mapping]; - NR

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; AMIO = amiodarone; CFAE = Complex fractionated atrial electrograms; CI = Confidence Interval; CPVA = circumferential pulmonary vein ablation; ECG = Electrocardiography; FU = Followup; IQR = Interquartile range; LO = losartan; NR = Not reported; PVI = Pulmonary Vein Isolation; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SD = Standard deviation; SPVI = segmental pulmonary vein isolation.

Table E7 Study Characteristics of RCTs Comparing Radiofrequency Catheter Ablation versus Medical Therapy in Patients with Paroxysmal Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Inclusion Criteria | Exclusion Criteria | Outcomes | Funding
Cosedis Nielsen (2012)54 Denmark, Finland, Sweden, Germany | - RCT; - Fair Quality; - Multicenter (# of sites NR); - AADs used only in medical treatment group; - 100% 1^st^ line therapy | - At least two episodes of symptomatic atrial fibrillation within the preceding 6 months; - No episode of atrial fibrillation that was longer than 7 days (without spontaneous termination or cardioversion) | - Age of more than 70 years; - Previous or ongoing treatment with class IC or class III antiarrhythmic drugs; - Contraindication to both class IC and class III agents; - Previous ablation for atrial fibrillation; - Left atrial diameter of more than 50 mm; - Left ventricular ejection fraction of less than 40%; - Contraindication to oral anticoagulation therapy; - Moderate-to-severe mitral valve disease; - Severe heart failure (NYHA functional class III to IV at the time of enrollment); - Expected surgery for structural heart disease; - Secondary atrial fibrillation (due to cardiac surgery, infection, or hyperthyroidism) | [underlined: Primary]; - SF-36: mental component summary, physical component summary; - Mortality (all cause) (timing of occurrence NR); - Mortality (cardiovascular) (timing of occurrence NR); - Transient ischemic attack (timing of occurrence NR); - Hospitalization/readmission for cardiovascular events (including AF); - Congestive heart failure; - Myocardial infarction (timing of occurrence NR); - Ventricular tachycardia and implantation of an ICD; [underlined: Secondary]; - Freedom from recurrence (AF only); - Freedom from symptomatic recurrence (AF only); - Repeat ablation for AF; - Repeat ablation for any arrhythmia (or cause NR); - Time to recurrent AF; - Drug therapy: Bradycardia; - Atrial flutter or atrial tachycardia; - AF burden; - Cumulative burden of symptomatic AF; [underlined: Adverse events]: various | - [underlined: Funding]: Biosense Webster (unrestricted grant) and Danish Heart Foundation (unrestricted grant); Finnish Foundation for Cardiovascular Research (grant); - [underlined: COI]: multiple authors report conflict of interest
Jais (2008)55 Canada, USA, France | - RCT; - Fair Quality; - Multicenter (4 sites); - AADs used only in medical treatment group; - 100% 2^nd^ line therapy | - Patients >18 years of age who were capable of providing informed consent; - Symptomatic, documented paroxysmal AF over a span of ≥6 months; - At least 2 episodes during the preceding month. | - Contraindications to >2 AADs in different classes or to oral anticoagulants; - Prior AF ablation; - Intracardiac thrombus; - AF from a potentially reversible cause; - Pregnancy; - Contraindication to the discontinuation of oral anticoagulation | [underlined: Primary]; - AF burden; - SF-36: physical component summary and mental component summary; - Stress test: exercise duration, heart rate at rest, maximum heart rate, maximum workload, METS; - Symptom checklist: frequency scale, severity scale; - Mortality (all cause) (time of occurrence NR); - Mortality (cardiovascular) (time of occurrence NR); - Myocardial infarction (time of occurrence NR); [underlined: Secondary]; - Freedom from recurrence (AF lasting ≥ 3 minutes and documented by ECG or reported by the patients as AF (even in the absence of ECG confirmation)); - Repeat ablation for any arrhythmia (or cause NR); - Reduced medication use; - LA size; - LV size; - Left ventricular ejection fraction (LVEF); - Maintenance of sinus rhythm; [underlined: Adverse events]: various | - [underlined: Funding]: Biosense Webster, Inc., St. Jude Medical, Bard, Medtronic, Biotronik, Canada Research Chair in Electrophysiology and Adult Congenital Heart Disease, Canadian Institute of Health Research, Fonds de Recherche en Sante, Boston Scientific, CryoCath Technologies; - [underlined: COI]: multiple authors report conflicts of interest
Morillo (2014)56 USA, Canada, Germany, Czech Republic, Italy | - RCT; - Fair Quality; - Multicenter (16 sites); - AADs used only in medical treatment group; - 100% 1^st^ line therapy | - Older than 18 and no older than 75 years; - Symptomatic with recurrent paroxysmal AF lasting more than 30 seconds (≤4 episodes within the prior 6 months); - Experienced at least 1 episode that was documented by surface ECG, 6 months before randomization; - No previous antiarrhythmic drug treatment | - Documented left ventricular ejection fraction of < 40%; - Left atrial diameter larger than 5.5 cm; - Moderate to severe left ventricular hypertrophy (wall thickness >1.5 cm), valvular disease, coronary artery disease, or postcardiac surgery within 6 months; - Undergone a left heart ablation procedure, either by surgery or by radiofrequency catheter ablation for AF; - Complete contraindication for the use of heparin, warfarin, or both | [underlined: Primary]; - Mortality (all cause) (timing of occurrence NR); - Stroke (any type) (timing of occurrence NR); - Mortality (cardiovascular) (timing of occurrence NR); - Total number of any atrial tachyarrhythmia episodes; - Time to second ablation; - EQ5D: visual analog score, tariff score, and anxiety or depression; [underlined: Secondary]; - Freedom from symptomatic AF lasting >30 seconds; - Freedom from recurrence of symptomatic or asymptomatic atrial tachyarrhythmia (AF, atrial flutter, atrial tachycardia) lasting > 30 seconds; - Freedom from symptomatic atrial tachyarrthythmia recurrence lasting >30 seconds; - Repeat ablation for any arrhythmia (or cause NR); - Drug therapy: Bradycardia; - Atrial flutter; - Arrhythmia (drug related); [underlined: Adverse effects]: various | - [underlined: Funding]: Biosense Webster (unrestricted research grant) and Population Health Research Institute at McMaster University; - [underlined: COI]: Multiple authors received grants and/or consulting fees from one or more of the following: Biosense Webster, Boston Scientific, Medtronic, St Jude Medical, Biotronik, Boehringer Ingelheim, Merck
Pappone (2006)57 Italy | - RCT; - Fair Quality; - Single center; - AADs used only in medical treatment group; - 100% 2^nd^ line therapy | - Age >18 or <70 years old; - Creatinine concentration < 1.5 mg/dl; - History of AF >6 months; - AF burden >2 episodes/month in the last 6 months before enrollment (quantified by review of patient charts) | - AF secondary to transient or correctable abnormality; - Intra-atrial thrombus or tumor precluding catheter insertion; - LA diameter >65 mm; - Left ventricular ejection fraction ≤35%; - Symptoms of heart failure greater than New York Heart Association functional class II; - Prior drug therapy with amiodarone, flecainide, and sotalol; - Contraindication to beta-blocking therapy; - Patients with rheumatic mitral valve disease; - Unstable angina or acute or prior myocardial infarction (< 6 months); - Wolff-Parkinson-White syndrome; - Renal or hepatic failure; - Implanted device (pacemaker or cardioverter-defibrillator); - Need for antiarrhythmic therapy for arrhythmias other than AF; - Contraindication to drug therapy or anticoagulation with warfarin; - History of a cerebrovascular accident; - Prior attempt at catheter or surgical ablation for AF | [underlined: Primary]; - None; [underlined: Secondary]; - Hospitalization. Readmission for cardiovascular events (including AF); - Repeat ablation for AF; - Freedom from any recurrence (Atrial tachyarrhythmias (including both AF and atrial tachycardia) beyond the first 6 weeks after the ablation); - LA size; - Maintenance of sinus rhythm; - Atrial flutter; - Hyperthyroidism (related to drug therapy); [underlined: Adverse events]: various | - [underlined: Funding]: NR; - [underlined: COI]: NR
Pappone (2011)58 Italy | - RCT; - Fair Quality; - Single Center; - AADs used only in medical treatment group; - 100% 2^nd^ line therapy | - Age >18 or <70 years; - AF history >6 months; - AF burden >2 episodes per month in the last 6 months as assessed by daily transtelephonic monitoring. | - Persistent AF; - LA diameter >65 mm; - LVEF ≤35%; - Heart failure symptoms; - New York Heart Association functional class II; - Residents outside of Italy | [underlined: Primary]:; - Transient ischemic attack after 30d; - Progression of paroxysmal to persistent AF; - SF-36: physical functioning, role limitations physical, bodily pain, general health, vitality, social functioning, role limitations emotional, mental health, physical component summary, mental component summary; [underlined: Secondary]:; - Freedom from recurrence (Atrial tachyarrhythmias (including both AF and atrial tachycardia) beyond the first 6 weeks after the ablation documented by Holter monitoring; - Hospitalization/readmission for cardiovascular events (including AF); - Repeat ablation for any arrhythmia (or cause NR); - Arrhythmia (drug related); [underlined: Adverse events]: various | - [underlined: Funding]: Arrhythmology Department at San Raffaele University Hospital; - [underlined: COI]: Dr. Pappone reports multiple conflicts of interest
Wazni (2005)59 Italy & Germany | - RCT; - Fair Quality; - Multicenter (3 sites; - AADs used only in medical treatment group; - 100% 1^st^ line therapy | - Ages 18 to 75 years; - Experienced monthly symptomatic AF episodes for ≥3 months; - Not been treated with antiarrhythmic drugs | - Ages <18 or >75 years; - Previous history of atrial flutter or AF ablation; - Previous history of open-heart surgery; - Previous treatment with antiarrhythmic drugs; - Contraindication to long-term anticoagulation treatment | [underlined: Primary]; - SF-36: general health, physical functioning, role limitations physical, bodily pain, mental health, social functioning, role limitations emotional, vitality; - Stroke (Any Type) (timing of occurrence NR); - Transient ischemic attack (timing of occurrence NR); - Mortality (all-cause) (timing of occurrence NR); - Mortality (cardiovascular) (timing of occurrence NR); [underlined: Secondary]; - Number and duration of episodes; - Ventricular rate; - Freedom from recurrence (Symptomatic or asymptomatic AF only lasting > 15 seconds during Holter or event monitoring in the 1-year followup period); - Repeat ablation for AF; - Hospitalization (cause NR); - Medication use (dosage and/ or frequency); - Incidence of Bradycardia; [underlined: Adverse events]: various | - [underlined: Funding]: unrestricted educational grant from Acuson, a division of Siemens Medical Solutions; - [underlined: COI]: NR
Wilber (2010)60 USA, Canada, “Latin America,” Europe (NR) | - RCT; - Fair Quality; - Multicenter (9 sites); - AADs used only in medical treatment group; - 100% 2^nd^ line therapy | - At least 3 symptomatic AF episodes (≥1 episode verified by ECG) within the 6 months before randomization; - Not responding to at least 1 antiarrhythmic drug (class I, class III, or atrioventricular nodal blocker) | - Patients with AF of more than 30 days duration; - Age younger than 18 years; - Ejection fraction of less than 40%; - Previous ablation for AF; - Documented left atrial thrombus; - Amiodarone therapy in the previous 6 months; - New York Heart Association class II (marked limitation in activity due to symptoms) or IV (sever limitations); - Myocardial infarction within the previous 2 months; - Coronary artery bypass graft procedure in the previous 6 months; - Thromboembolic event in the previous 12 months; - Severe pulmonary disease; - Prior valvular cardiac surgical procedure; - Presence of an implanted cardioverter-defibrillator; - Contraindication to antiarrhythmic or anticoagulation medications; - Life expectancy <12 months; - Left atrial size of at least 50 mm in the parasternal long axis view | [underlined: Primary]; - Mortality (all-cause) after 30d; - Myocardial infarction after 30d; - Mortality (cardiovascular) after 30d; - SF-36: Mental component summary and physical component summary; - Symptom checklist: frequency scale and severity scale; [underlined: Secondary]; - Freedom from symptomatic recurrence (Symptomatic or asymptomatic AF only lasting >15 seconds during Holter or event monitoring in the 1-year followup period); - Freedom from protocol defined treatment failure; [underlined: Adverse events]: various | - [underlined: Funding]: Biosense Webster; - [underlined: COI]: Multiple authors received grants and/or consulting fees from various industries (e.g. Biosense Webster, Boston Scientific, Medtronic, St Jude Medical, Johnson & Johnson, etc.)

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; COI = conflict of interest; ECG = Electrocardiography; EF = Ejection Fraction; FU = Followup; ICD = International Classification of Diseases; LA = Left Atrium; LV = Left ventricle; LVEF = Left ventricular ejection fraction; METs = Metabolic equivalents of task; NR = Not reported; NYHA = New York Heart Association; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SF-36 = Short Form-36; QoL = Quality of Life.

Table E8 Study Characteristics of RCTs Comparing Radiofrequency Catheter Ablation Versus Medical Therapy in Patients with Persistent Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Inclusion Criteria | Exclusion Criteria | Outcomes | Funding
Hunter (2014)61 United Kingdom | - RCT (CAMTAF Trial); - Fair quality; - Single center; - AADs used in both treatment groups; - 100% 1^st^ line therapy | - Patients ≥18 years; - Persistent AF; - Symptomatic HF (New York Heart Association functional class II – IV); - LV systolic dysfunction (ejection fraction <50%); - <80 bpm resting heart rate; - <110 bpm heart rate upon moderate exertion as assessed on ambulatory monitoring and exercise testing | - HF with suspected reversible cause; - Previous left atrial ablation; - Any contraindications to catheter ablation; - Paroxysmal AF; - Symptoms clearly attributable to AF rather than HF i.e., palpitations or dizziness that might mandate a rhythm control strategy; - Any event during the past 6 months that might continue to effect on LV function, or a realistic expectation of these occurring within the next year | [underlined: Primary]; - Intracranial hemorrhage; - Peak oxygen consumption (VO2); - New York Heart Association (NYHA) score; - Minnesota Living with Heart Failure Questionnaire (MLHFQ); [underlined: Secondary]; - Freedom from recurrence; - Reablation; [underlined: Adverse events]; - Stroke; - Tamponade; - Intracranial hemorrhage^*^; - Cardiac death^*^ | - [underlined: Funding:] British Heart Foundation grant (PG/08/130); - [underlined: COI:] the authors indicate no conflict of interest
MacDonald (2011)62 Scotland | - RCT; - Fair Quality; - Multicenter (6 sites); - AADs used in both treatment groups; - 100% 1^st^ line therapy | - Patients ages 18–80 years; - New York Heart Association functional class II-IV symptoms despite optimal heart failure treatment for ≥3 months; - Ejection fraction ≤35% measured by radionuclide ventriculography; - Persistent AF; - No contraindication to cardiovascular MRI | - Paroxysmal AF; - QRS duration >150ms (or QRS 120–150 with evidence of mechanical cardiac dysynchrony); - Any contraindication to oral anticoagulant drugs; - Primary vascular disease or acute myocarditis as the cause of heart failure; - Coronary revascularization within the preceding 6 months; - Pregnancy; - Expected cardiac transplantation within 6 months | [underlined: Primary]; - SF-36: mental component summary and physical component summary; - 6-minute walk distance; - Kansas City Cardiomyopathy Questionnaire (KCCQ); - Minnesota Living with Heart Failure Questionnaire (MLHFQ); [underlined: Secondary]; - LA size; - Left ventricular end-systolic volume; - Left ventricular end-diastolic volume; - Maintenance of sinus rhythm; - Repeat ablation for AF; - Left and right ventricular ejection fraction (LVEF & RVEF); [underlined: Adverse events:] various | - [underlined: Funding:] Chief Scientist Office, Scotland (grant number CZB4475); - [underlined: COI:] the authors indicate no conflict of interest
Mont (2014)63 Spain | - RCT; - Fair Quality; - Multicenter (8 sites); - AADs used in both treatment groups; - 100% 2^nd^ line therapy | - Patients with symptomatic persistent atrial fibrillation (greater than 7 or less than 7 days requiring electrical or pharmacological cardioversion); - Refractory to at least one class I or class III antiarrhythmic drug were recruited. | - Age <18 or >70 years,; - Long-standing persistent AF (greater than 1 year of continuous AF); - First episode of AF; - Hyper- or hypothyroidism; - Hypertrophic cardiomyopathy; - Implanted pacemaker or defibrillator; - Moderate or severe mitral disease or mitral prosthesis; - Left ventricular ejection fraction less than 30 percent; - Left atrial diameter greater than 50mm; - Prior ablation procedure; - Contraindication for oral anticoagulation; - Left atrial thrombus; - Active infection or sepsis; - Pregnancy; - Unstable angina; - Acute myocardial infarction during previous 3 months; - Life expectation <12 months; - Current participation in another clinical trial; - Mental disease or inability to give informed consent; - Disease contraindicating ablation or AAD therapy | [underlined: Primary]; - Mortality (all-cause) (timing of occurrence NR); - Mortality (cardiovascular) (timing of occurrence NR); - Transient ischemic attack (timing of occurrence NR); - Stroke (any type) (timing of occurrence NR); - AF-QoL (physical domain, global score, sexual domain, psychological domain); - Cardioversions (2 or more); [underlined: Secondary]; - Freedom from recurrence (AF or flutter lasting ≥30 seconds after a 3-month blanking period); - Hospitalization/ readmission for cardiovascular events (including AF); - Repeat ablation for AF; - Repeat ablation for any arrhythmia (or cause NR); [underlined: Adverse events:] various | - [underlined: Funding:] Unrestricted grant from Medtronic and Biosense Webster, and a grant from Hospital Clinic (premi de Fi de Residencia Emili Letang).; - [underlined: COI:] The authors report no conflict of interest
Oral (2006)64 USA, Italy | - RCT; - Fair Quality; - Multicenter (2 sites); - AADs used only in medical treatment groups; - 100% 2^nd^ line therapy | - Patients with chronic atrial fibrillation defined as atrial fibrillation that had been present for more than six months without intervening spontaneous episodes of sinus rhythm and that recurred within one week after cardioversion. | - Age <18 or >70 yr; - Left atrial diameter >55 mm; - Left ventricular ejection fraction <30 percent; - Contraindication to amiodarone therapy or anticoagulation with warfarin; - Presence of a mechanical prosthetic valve; - History of a cerebrovascular accident; - Presence of left atrial thrombus on transesophageal echocardiography; - Prior attempt at catheter or surgical ablation for atrial fibrillation | [underlined: Primary:]; - Mortality (all-cause) after 30d; [underlined: Secondary:]; - Freedom from recurrence (Symptomatic or asymptomatic AF only lasting >15 seconds during Holter or event monitoring in the 1-year followup period); - Repeat ablation for any arrhythmia (or cause NR); - Repeat ablation for AF; - Freedom from Bradyarrhythmia (sick sinus syndrome); [underlined: Adverse events:] various | - [underlined: Funding:] The Ellen and Robert Thompson Atrial Fibrillation Research Fund (Ann Arbor, Mich.); - [underlined: COI:] Drs. Oral and Morady are founders of Ablation Frontiers, report being major stockholders in Ablation Frontiers, and report having served as consultants to Ablation Frontiers and Biosense Webster. Dr. Pappone reports having received grant support from Biosense Webster, St. Jude Medical, Guidant, and Medtronic and having served as a consultant to Biosense Webster. Dr. Chugh reports having received lecture fees from Biosense Webster.
Jones (2013)65 UK | - RCT; - Fair Quality; - Multicenter (2 sites); - AADs used only in medical treatment group; - Both 1^st^ and 2^nd^ line therapy | - 18 to 80 years of age; - Persistent AF (>7 days); - Symptomatic HF (New York Heart Association functional class II to IV) on optimal HF therapy; - Left ventricular ejection fraction (EF) ≤35% | - Cardiovascular implantable electronic device insertion or cerebrovascular event within 6 months; - Coronary revascularization or atrioventricular nodal ablation within 3 months; - Reversible causes of AF or HF including thyroid dysfunction, alcohol, primary valvular disease, or recent major surgery; - Prior heart transplant or on urgent transplant waiting list; pregnancy; - Active malignancy; - Severe renal impairment; - Single chamber pacemaker and atrioventricular block; - Contraindications to general anesthesia or oral anticoagulation | [underlined: Primary:]; - Peak oxygen consumption (VO2); - Minnesota Living with heart Failure Questionnaire (MLHVQ); - 6-minute walk distance; - Mortality (cardiovascular) after 30d; - Mortality (all cause) after 30d; [underlined: Secondary:]; - Repeat ablation for AF; - Repeat ablation for any arrhythmia (or cause NR); - Freedom from recurrence (Atrial arrhythmia (assessed by ECG) lasting >30 seconds, occuring during the post-blanking period)); - Biomarker: brain (or B-type) natriuretic peptide; - Left ventricular ejection fraction (LVEF); - Left atrial size; - Single procedure success; - Multi-procedure success; - Mean arrhythmia-free survival time; - Maintenance of sinus rhythm; - Mean time to first atrial arrhythmia recurrence; [underlined: Adverse events:] various | - [underlined: Funding:] National Institute for Health Research cardiovascular Biomedical Research Unit; - [underlined: COI:] multiple authors report conflict of interest

AAD = antiarrhythmic drugs; AF = Atrial Fibrillation; AF-QoL domain = Atrial Fibrillation Quality of Life Domain; COI = conflict of interest; ECG = Electrocardiography; EF = Ejection Fraction; FU = Followup; HF = heart failure; ICD = International Classification of Diseases; KCCQ = Kansas City Cardiomyopathy Questionnaire; LA = Left Atrium; LV = Left ventricle; LVEF = Left ventricular ejection fraction; METs = Metabolic equivalents of task; MLHFQ = Minnesota Living with Heart Failure Questionnaire; NR = Not reported; NYHA = New York Heart Association; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; RVEF = right ventricular ejection fraction; SF-36 = Short Form-36; VO2 = oxygen consumption; QoL = Quality of Life.

* These results only reported for the medical group.

Table E9 Study Characteristics of RCTs Comparing Radiofrequency Catheter Ablation Versus Medical Therapy in Patients with Paroxysmal or Persistent Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Inclusion Criteria | Exclusion Criteria | Outcomes | Funding
Forleo (2009)66 Italy | - RCT; - Fair Quality Multicenter (3 sites); - AADs used only in medical treatment group; - 100% 2^nd^ line therapy | - Diabetes mellitus type 2 patients; - Symptomatic paroxysmal or persistent AF for at least 6 months; - Refractory to at least one class 1–3 antiarrhythmic drugs | - Age <18 or >75 years; - Prior cardiac surgery; - History of previous ablation for AF; - Ejection fraction ≤30%; - Left atrial size >55mm; - Absence of informed patient consent; - Any condition that would make survival for 1 year unlikely. | [underlined: Primary]:; - SF-36: general health, social and physical functioning, bodily pain, role limitations emotional, mental health, vitality, role limitations physical; - Transient ischemic attack (timing of occurrence NR); - Stroke (any type) (timing of occurrence NR); [underlined: Secondary]:; - Freedom from recurrence (Any ECG confirmed episode of AF or atypical atrial flutter lasting 30 seconds, occurring between 5 weeks and 12 months); - Hospitalization (cause NR); [underlined: Adverse events]: various | - [underlined: Funding]: NR; - [underlined: COI]: Last author receives lecture fees from St. Jude Medical and serves on the advisory board of Biosense-Webster
Stabile (2006)67 Italy | - RCT; - Good Quality; - Multicenter (# of sites NR); - AADs used in both treatment groups; - 100% 2^nd^ line therapy | - Patients with paroxysmal (occurrence, in the previous 6 months, of one or more episodes of AF a month, each lasting > 60 min but < 7 days, with all episodes terminating spontaneously) or persistent (occurrence, in the previous 12 months, of two or more episodes of AF, each lasting > 7 days before being terminated pharmacologically or by electrical cardioversion, or lasting < 7 days but necessitating early cardioversion owing to intolerable symptoms or haemodynamic compromise, with sinus rhythm maintained for 60 min or more after termination) AF who were intolerant of antiarrhythmic drugs or in whom two or more antiarrhythmic drug regimens had failed.; - First diagnosis of AF had been made at least 6 months before enrollment. | - Age <18 or >80 years; - Permanent AF (AF was the sole rhythm for the last 12 months); - AF secondary to a transient or correctable abnormality, including electrolyte imbalance, trauma, recent surgery, infection, toxic ingestion, and endocrinopathy; - Persistence of AF episodes triggered by another uniform arrhythmia (i.e. atrial flutter or atrial tachycardia) despite previous supraventricular tachycardia ablation; - Intra-atrial thrombus, tumour, or other abnormality precluding catheter insertion; - Wolff–Parkinson–White syndrome; - Heart failure with NYHA class III or IV or EF ≤35%; - Unstable angina or acute myocardial infarction within 3 months; - Cardiac revascularization or other cardiac surgery within 6 months or with prior atrial surgery; - Renal failure requiring dialysis, or hepatic failure; - An implanted device (pacemaker or cardioverter-defibrillator).; - Left atrial diameter > 60 mm | [underlined: Primary]:; - Mortality (all-cause) (timing of occurrence NR); - Transient ischemic attack (timing of occurrence NR); [underlined: Secondary]:; - Freedom from recurrence (At least one occurrence of atrial arrhythmia (flutter or fibrillation) lasting > 30 seconds, in the 1 year followup period, after the 1-month blanking period); - Hospitalization (cause NR); [underlined: Adverse events]: various | - [underlined: Funding:] The trial was partly supported by Biosense- Webster, Italy.; - [underlined: COI]: Authors report that there are no conflicts of interest besides their received finding.

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; COI = conflict of interest; ECG = Electrocardiography; EF = Ejection Fraction; FU = Followup; ICD = International Classification of Diseases; LA = Left Atrium; LV = Left ventricle; LVEF = Left ventricular ejection fraction; METs = Metabolic equivalents of task; NR = Not reported; NYHA = New York Heart Association; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SF-36 = Short Form-36; QoL = Quality of Life.

Table E10 Study Characteristics of Observational Studies Comparing Radiofrequency Catheter Ablation Versus Medical Therapy in Patients with Paroxysmal Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Inclusion Criteria | Exclusion Criteria | Outcomes | Funding
Lan (2009)68 China | - Prospective, comparative observational; - Fair quality; - Single center; - 100% 2^nd^ line therapy | - Frequency of AF attack is at least one times monthly, which was documented by Holter or 12-lead ECG; - Presence of obvious symptoms of palpitations, chest distress during occurrence of AF; - New York Heart Association Class I and left ventricular ejection fraction (LVEF) >/= 55%(measured by transthoracic echocardiogram); - No structural heart diseases and blood pressure </= 165 / 95 mmHg in hypertensive patients | - Patients refractory to amiodarone in the past; - Left atrium (LA) size more than 45 mm; - Hyperthyroidism or electrolyte disturbance, pulmonary, or hepatic disease and/or contraindications to treatment with amiodarone, significant impairment of renal function, mitral regurgitation; - QT interval ‡ 480 ms in the absence of bundle branch block; - Bradycardia £ 55 bpm while the patient was awake; - Significant alternations of the atrioventricular conduction, sick sinus syndrome, or any other medical condition that, in the opinion of the investigators, could make the patient inappropriate for the study | [underlined: Primary]; - Blood pressure (diastolic); - Blood pressure (systolic); [underlined: Secondary]; - LA size; - Freedom from recurrence (AF >30 seconds); [underlined: Adverse events]: various | - [underlined: Funding]: grant from Health Research Foundation (Health bureau of Chongqing); - [underlined: COI]: the authors indicate no conflict of interest
Sang (2013)69 China | - Prospective, comparative observational; - Fair quality; - Single center; - 100% 2^nd^ line therapy | - Patients with symptomatic paroxysmal AF | - Age <18 years; - Contraindication to anticoagulation; - Previous nonpharmacological interventions for AF; - New York Heart Association functional class III or IV; - Myocardial infarction; - Cardiac surgery or transient ischemic attack/stroke within the previous 6 months; - Malignancy of any type, and presence of an implanted cardioverter defibrillator | [underlined: Primary]; - Zung Self-Rating Anxiety Scale (SAS) – total score; - Zung Self-Rting Depression Scale (SDS) – total score; - SF-36: mental component summary (MCS) and physical component summary (PCS); - Thromboembolic events; [underlined: Secondary]; - Repeat ablation for AF; - Freedom from recurrence (any symptomatic episodes of documented atrial tachyarrhythmias lasting ≥30 seconds, as well as any episode of asymptomatic atrial tachyarrhythmias lasting ≥10 minutes on 24-hour ambulatory Holter recordings); - Maintenance of sinus rhythm; [underlined: Adverse events]: various | - [underlined: Funding]: government, and the National Science Foundation Council of China (No. 30971239 and No. 81070147) and the Beijing Natural Science Foundation (No. 7101004); - [underlined: COI]: the authors indicate no conflict of interest
Yu (2012)70 China | - Retrospective, comparative observational; - Poor quality; - Single center; - 100% 2ns line therapy | - NR | - History of myocardial infarction in the last 12 months; - Cardiac surgery; - Congenital heart disease; - Pericardial disease; - History of cancer; - Tuberculosis; - Hyperthyroidism or hypothyroidism; - Rheumatism; - Decompensated liver cirrhosis; - Serum creatinine level >2 mg/dL | [underlined: Primary]; - Zung Self-Rating Anxiety Scale (SAS) – total score, normalized score; - Zung Self-Rating Depression Scale (SDS) – total score, normalized score; - SF-36: bodily pain, general health, mental health, physical functioning, role limitations emotional, role limitations physical, social functioning, vitality; [underlined: Secondary]; - Freedom from recurrence (AF >30 seconds); [underlined: Adverse events]: NR | - [underlined: Funding]: NR; - [underlined: COI]: the authors report no conflict of interest

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; COI = conflict of interest; ECG = Electrocardiography; EF = Ejection Fraction; FU = Followup; ICD = International Classification of Diseases; LA = Left Atrium; LV = Left ventricle; LVEF = Left ventricular ejection fraction; METs = Metabolic equivalents of task; NR = Not reported; NYHA = New York Heart Association; nonRCT = Nonrandomized Controlled Trial; RFA = Radiofrequency Ablation; SF-36 = Short Form-36; QoL = Quality of Life.

Table E11 Study Characteristics of Observational Studies Comparing Radiofrequency Catheter Ablation Versus Medical Therapy in Patients with Persistent Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Inclusion Criteria | Exclusion Criteria | Outcomes | Funding
Blandino (2013)71 Italy | - Prospective, comparative observational; - Fair quality; - Number of centers NR; - 100% 2^nd^ line therapy | - Patients aged 70 or greater; - Persistent and symptomatic AF; - AF refractory to at least one antiarrhythmic medication; - At least one episode of AF documented by ECG or Holter monitoring within 12 months of study enrollment; - Continuous anticoagulation with target international normalized ratio (INR) of 2–3 for at least 4 weeks before the procedure; - Written informed consent to participate in the study | - Paroxysmal and longstanding persistent AF; - Previous AF ablation procedure; - Cardiac surgical procedure in the previous 6 months; - Documented left atrial (LA) thrombus; - INR < 2 at admission and in the last 4 weeks before the procedure; - New York Heart Association (NYHA) class III or IV; - Acute myocardial infarction within the previous 2 months; - Severe pulmonary disease; - Contraindications to antiarrhythmic or anticoagulation medications; - inability to give written informed consent | [underlined: Primary]; - Mortality (cardiovascular) after 30d; - Stroke/ TIA (undefined) after 30d; - Myocardial infarction after 30d; - Peripheral embolism after 30d; - Congestive heart failure; - SF-36: bodily pain, general health, mental health, physical functioning, role limitations emotional, role limitations physical, social functioning, vitality; [underlined: Secondary]; - Repeat ablation for any arrhythmia (or cause NR); - Maintenance of sinus rhythm; - Freedom from recurrence (any episode of AF or atrial tachycardia lasting >30 seconds documented by an ECG); [underlined: Adverse events]: various | - [underlined: Funding]: NR; - [underlined: COI]: Dr. Blandino’s fellowship was sponsored by Biosense-Webster

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; COI = conflict of interest; ECG = Electrocardiography; EF = Ejection Fraction; FU = Followup; ICD = International Classification of Diseases; LA = Left Atrium; LV = Left ventricle; LVEF = Left ventricular ejection fraction; METs = Metabolic equivalents of task; NR = Not reported; NYHA = New York Heart Association; nonRCT = Nonrandomized Controlled Trial; RFA = Radiofrequency Ablation; SF-36 = Short Form-36; QoL = Quality of Life.

Table E12 Study Characteristics of Observational Studies Comparing Radiofrequency Catheter Ablation Versus Medical Therapy in Patients with Paroxysmal or Persistent Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Inclusion Criteria | Exclusion Criteria | Outcomes | Funding
Reynolds (2012)72 USA | - Retrospective comparative observational; - From matched cohort administrative database (MarketScan Research Database, Thomson Reuters); - AF type NR; - 100% 2^nd^ line | - In patient or outpatient visit with both a recorded diagnosis of AF (ICD-9 code 427.31) and a documented catheter ablation procedure (ICD-9 code 37.34 or CPT code 93651) | - Code designating a pacemaker or implantable cardioverter defibrillator implantation; - Record of any cardiac ablation procedure before the first procedure meeting inclusion requirements; - Procedure code for open (surgical) ablation procedure or atriventricular junction ablation at the same visit | [underlined: Primary]; - Stroke/TIA; - Heart failure hospitalization; [underlined: Secondary]; - Medication use; [underlined: Adverse events]: NR | - [underlined: Funding:] Biosense Webster, Inc, Diamond Bar, CA; - [underlined: COI:] Multiple authors report funding and/or paid consulting and/or employment from Biosense Webster, Inc; Sanofi Adventis, St Jude Medical; Medtronic, Inc; and S^2^ Statistical Solutions, Inc.
Rossillo (2008)73 Italy | - Retrospective, comparative observational; - Poor quality; - Single center; - 2^nd^ line therapy for RFA group, NR for Med group | - NR | - NR | [underlined: Primary]; - Stroke (any type) after 30d; - Mortality (all cause ) after 30d; [underlined: Secondary]; - Freedom from recurrence (Symptomatic or asymptomatic AF); - Freedom from recurrence (any arrhythmia); [underlined: Adverse events]: various | - [underlined: Funding:] NR; - [underlined: COI]: NR
Sonne (2009)74 USA | - Retrospective, comparative observational; - Poor Quality; - Single center; - 100% 2^nd^ line therapy | [underlined: Ablation]; - PVAI; - No prior or subsequent ablative or surgical treatment for AF such as AV node junction ablation or Cox–Maze procedure; - Symptomatic AF refractory to ≥1 AADs; [underlined: Medical Therapy]; - Had pharmacologic therapy combined with DCC; - No prior or subsequent ablative or surgical treatment for AF such as AV node junction ablation, PVI, or maze procedure; - Majority of patients had multiple DCCVs (Did not report criteria for AVJA since it's excluded) | - NR | [underlined: Primary]; - Mortality (all cause) (timing of occurrence NR); - Mortality (cardiovascular) (timing of occurrence NR); - Congestive heart failure; - Myocardial infarction (timing of occurrence NR); - Stroke (any type) (timing of occurrence NR); [underlined: Secondary]; - Freedom from recurrence (AF that persists 8 weeks after ablation); [underlined: Adverse effects]: various | - [underlined: Funding]: NR; - [underlined: COI]: NR

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; AV = Atrioventricular; AVJA = atrioventricular junctional ablation; COI = conflict of interest; DCC = direct current cardioversion; ECG = Electrocardiography; EF = Ejection Fraction; FU = Followup; ICD = International Classification of Diseases; LA = Left Atrium; LV = Left ventricle; LVEF = Left ventricular ejection fraction; METs = Metabolic equivalents of task; NR = Not reported; NYHA = New York Heart Association; nonRCT = Nonrandomized Controlled Trial; PVI = pulmonary vein isolation; RFA = Radiofrequency Ablation; SF-36 = Short Form-36; QoL = Quality of Life.

Table E13 Demographics of Included RCTs Comparing Cryoballoon Ablation with Medical Therapy in Patients with Paroxysmal/Early Persistent Atrial Fibrillation

Author (year) | Study Design (Quality rating) | Demographics | Patient Characteristics | Followup Blanking Period % Crossover | Interventions
Packer (2013)75 Andrade (2014) US Canada | - RCT (STOP-AF trial); - Fair quality; - Multicenter (26 sites); - 2^nd^ line therapy | N = 245 77.1% male Age = 57 ± 9 years [underlined: Cryo]: n = 163 76.7% male Age = 57 ± 9 years [underlined: Medical]: n = 82 78% male Age = 56 ± 9 years [underlined: Special Population]: None | [underlined: Left Atrial diameter]: Cryo: 40 ± 5 mm Med: 41 ± 6 mm [underlined: AF Duration]: NR [underlined: No. AF episodes in prior 2 months] Cryo: 24 ± 42 Med: 21 ± 32 | [underlined: FU]: 12 months 98.8% (242/245) [underlined: Cryo]: 100% (163/163) [underlined: Med]: 96.3% (79/82) [underlined: Blanking period]: Cryo: 90 days Med: 90 days [underlined: % Crossover]: Cryo: NR Med: 79.3% (65/82) | [underlined: Cryoballoon Ablation]:; - PV isolation of the four major PV’s 97.6% (159/163); - PVI achieved with the balloon catheter alone in 83% (135/163); - Additional catheter based focal cryoablation in one or more PVs for 16.6% (27/163); - Left common PV isolation 100% (21/21); - Right middle PVs 76.9% (10/13); - Cavotricuspid isthmus ablation with bidirectional block achieved in 97% (64/66); - 74.2% (121/163) patients received AADs after cryoballoon ablation, but these drugs were discontinued after the blanking period. At the end of 12 months, 26% of patients were taking AADs.; [underlined: Medical Therapy] (dosages according to 2006 AHA/ACC guidelines):; - Flecainide 65%; - Propafenone 57%; - Sotalol 44%; [underlined: Mapping]:; - Pacing and a circular mapping catheter used to assess entrance and/or exit blockage after a 30 min waiting period

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; COI = conflict of interest; ECG = Electrocardiography; EF = Ejection Fraction; FU = Followup; ICD = International Classification of Diseases; LA = Left Atrium; LV = Left ventricle; LVEF = Left ventricular ejection fraction; METs = Metabolic equivalents of task; NR = Not reported; NYHA = New York Heart Association; nonRCT = Nonrandomized Controlled Trial; RFA = Radiofrequency Ablation; SF-36 = Short Form-36; QoL = Quality of Life.

Table E14 Study Characteristics of Included RCTs Comparing Cryoballoon Ablation with Medical Therapy in Patients with Paroxysmal/Early Persistent Atrial Fibrillation

Author (year) | Study Design (Quality rating) | Inclusion Criteria | Exclusion Criteria | Outcomes | Funding
Packer (2013)75 Andrade (2014) US Canada | - RCT (STOP-AF trial); - Fair quality; - Multicenter (26 sites); - 2^nd^ line therapy | - Patients with more than 2 episodes of paroxysmal atrial fibrillation in the 2 months prior to randomization; - Treatment failure of least one membrane-active drug | - Left atrium (LA) >5.0 cm; - Left ventricular ejection fraction <40%; - New York Heart Association functional class III or IV congestive heart failure; - Coronary artery disease warranting intervention; - Stroke or transient ischemic attack within 6 months; - Previous LA ablation or surgery for AF; - A prosthetic heart valve; - Amiodarone therapy in the preceding 3 months; - More than 2 cardioversions within 2 years; - Have an implantable rhythm device | [underlined: Primary]; - Myocardial infarction after 30d; - Mortality (cardiovascular) after 30d; [underlined: Secondary]; - Freedom from recurrence (any detectable AF after the blanking period); - Freedom from protocol defined treatment failure; - Symptom reduction; [underlined: Adverse events]: various | - [underlined: Funding]: funded by Medtronic, Inc. (which purchased Cryocath over the course of the study).; - [underlined: COI]: various

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; COI = conflict of interest; ECG = Electrocardiography; EF = Ejection Fraction; FU = Followup; ICD = International Classification of Diseases; LA = Left Atrium; LV = Left ventricle; LVEF = Left ventricular ejection fraction; METs = Metabolic equivalents of task; NR = Not reported; NYHA = New York Heart Association; nonRCT = Nonrandomized Controlled Trial; RFA = Radiofrequency Ablation; SF-36 = Short Form-36; QoL = Quality of Life.

Table E15 Demographics of Included RCTs and Comparative Observational Studies Comparing Ablation with Different Energy Sources in Patients with Paroxysmal Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Demographics | Patient Characteristics | Followup Blanking Period % Crossover | Interventions
Perez- Castellano (2014)76 Spain | - RCT (COR Trial); - Fair quality; - Single center; - 100% 2^nd^ line therapy | N = 50 78% male Age = 57 years [underlined: RFA:] n = 25 88% male Age = 56 (40 – 61) years (median, IQR) [underlined: Cryo:] n = 25 68% male Age = 58 (45 – 62) years (median, IQR) [underlined: Special Population:] Refractory to AADs (Class I or III) | [underlined: Left atrial diameter:] RFA: 42 (38 – 45) mm (median, IQR) (parastemal long-axis echocardiographic view) Cryo: 42 (39 – 47) mm (median, IQR) (paratemal long-axis echocardiographic view) [underlined: AF Duration:] NR | [underlined: FU:] NR; 12 mo [underlined: Blanking period:] 3 mo [underlined: % crossover:] NR | [underlined: RFA Ablation:]; - Ostial PVI 100%; - Right inferior PV (1% each group); - Bidirectional block (83% cryo, 100% RFA); - Cavotricuspid isthmus ablation (4% cryo, 5% RFA); - Systemic anticoagulation with intravenous heparin; - AADs could be prescribed temporarily within a 3-month blanking period, which were discontinued after end of blanking period; [underlined: Cryoballoon Ablation:]; - The cryoballoon was positioned in the targeted PV (or PVs) where 2 consecutive 300-second applications were delivered; - Systemic anticoagulation with intravenous heparin (dose NR); - AADs could be prescribed temporarily within a 3-month blanking period, which were discontinued after end of blanking period; - Touch-up: cavotricuspid isthmus ablation 4%; [underlined: Mapping:]; - RFA: CARTO electroanatomical mapping system (Biosense Webster, Tirat-Hacarmel, Israel); - Selective PV angiograms were obtained through a 6-F angled pigtail catheter (Supertorque Plus, Cordis Corp, Miami, FL); - Cryo: 15-mm-diameter circular decapolar catheter (Lasso, Biosense Webster Inc, Diamond Bar, CA)
Chierchia (2010)77 Belgium | - Prospective, comparative observational; - Poor quality; - Single center; - 100% 2^nd^ line therapy | N = 133 79% male Age = 56 years [underlined: RFA:] n = 87 79% male Age = 56 ± 9 years [underlined: Cryo:] n = 46 78% male Age = 56 ± 11 years [underlined: Special Population:] No | [underlined: Left atrial diameter:] RFA: 42 ± 5 mm (transthoracic examination) Cryo: 41 ± 5 mm (transthoracic examination) [underlined: AF Duration:] RFA: 3.2 ± 1.7 years Cryo: 3.3 ± 1.9 years | [underlined: FU:] 100% (133/133); 24 hours of the procedure [underlined: Blanking period:] NR [underlined: % crossover:] NR | [underlined: RFA Ablation:]; - Circumferential PVI with no additional lines 100%; - No usage of AADs; [underlined: Cryoballoon Ablation:]; - The cryoballoon was positioned in the PV ostium of each vein with a minimum of two applications lasting for 5 minutes each %NR (n’s NR); - No usage of AADs; - Touch-up: no touch ups performed; [underlined: Mapping:]; - Cryo: A circular mapping catheter (Lasso, Biosense Webster, Inc., Diamond Bar, CA, USA) was advanced in each PV ostium to obtain baseline electrical information of the PVs and the left atrium; - RFA: electroanatomical mapping (Carto, Biosense Webster, Diamond Bar, CA, USA)
Knecht (2014)78 Switzerland | - Prospective comparative observational (BEAT-AF-PVI cohort study); - Fair quality; - Multicenter (2 sites); - 2^nd^ line therapy | N = 142 54% male Age = 58.2 years [underlined: RFA:] n = 71 77.5% male Age = 57.8 ± 11.2 years [underlined: Cryo:] n = 71 74.7% male Age = 58.6 ± 10.6 years [underlined: Special Population:] No | [underlined: Left atrial diameter:] RFA: 39.2 ± 5.3 mm, median 39 mm (mode NR) Cryo: 39.5 ± 6.0 mm, median 40 mm (mode NR) [underlined: AF duration:] RFA: 57 ± 70 months, median 36 months Cryo: 67 ± 70 months, median 52 months | [underlined: FU:] %NR; mean followup 28 mo [underlined: Blanking period:] 3 mos [underlined: % crossover:] 28.1% (20/71) patients | [underlined: RFA Ablation:]; - Acute PCI 100%; - AADs discontinued after procedure; [underlined: Cryoballoon Ablation:]; - A freezing cycle with a standard duration of 300 s was started after PV occlusion was demonstrated by contrast ejection; [underlined: Cryoballoon + RFA Ablation:]; - If ablation using CB alone was not effective in isolating PV after up to a max of 4 applications, PVI was completed as described above 28.1% (20/71)^†^; - AADs discontinued after procedure; [underlined: Mapping:]; - Cryo: Circumferential mapping catheter (manufacturer NR); - RFA: 3D-mapping system and a 3.5 mm open irrigated-tip catheter (manufacturer NR)
Mugnai (2014)79 Belgium, Italy | - Retrospective, comparative observational; - Poor quality; - Single center; - 2^nd^ line therapy | N = 396 70.5% male Age = 57.8 years [underlined: RFA:] n = 260 69.6% male Age = 58.3 ± 8.7 (30 – 77, 60) (median IQR, mean) [underlined: Cryo:] n = 136 72.1% male Age = 57 ± 13.3 (15 – 78, 56) [underlined: Special Population:] No | [underlined: Left atrial diameter:] RFA: 42.8 ± 5.7 (42.6) mm (median) Cryo: 41.8 ± 6.8 (42) mm (median) [underlined: AF duration:] RFA: 25.4 ± 37.1 (10) months (median) Cryo: 25.1 ± 24 (10.5) months (median) | [underlined: FU:=] %NR; 23 ± 13.4 mo, median 27 mo [underlined: Blanking period:] 3 mo [underlined: % crossover:] NR | [underlined: RFA Ablation:]; - PVI 100%; - Contiguous focal lesions were created at a distance of >5 mm from the ostia of PVs resulting in circumferential lines around ipsilateral PVs; - Each application lasted a maximum of 60 seconds; - AADs administered for 2 months after procedure and stopped if patient was free of AF relapse (dose NR); - Oral anticoagulants started day after procedure and continued for 3 months (dose NR); - Low molecular weight heparin started upon patient discharge and stopped when target international normalized ration of 2 – 3 was reached (dose NR); [underlined: Cryoballoon Ablation:]; - PVI 100%; - CB was advanced over to the left atrium, inflated, and positioned in the PV ostium of each vein; - Minimum of 2 applications lasting 5 minutes each; - AADs administered for 2 months after procedure and stopped if patient was free of AF relapse (dose NR); - Oral anticoagulants started day after procedure and continued for 3 months (dose NR); - Low molecular weight heparin started upon patient discharge and stopped when target international normalized ration of 2 – 3 was reached (dose NR); - Touch-up: Focal touch-up with either a focal-tip cryocatheter (Freezor Max; CryoCath Technologies Inc., Montreal, Quebec, Canada) or an irrigated-tip RF catheter (NaviStar ThermoCool; Biosense Webster Inc.) (3.7%, 5/136); [underlined: Mapping:]; - RFA: Circumferential mapping catheter (Lasso; Biosense Webster, Inc., Diamond Bar, CA) was positioned into proximal portion of the PV ostium, whereupon an electroanatomic map of the left atrium was performed with a nonfluoroscopic navigation system (CARTO; Biosense Webster Inc.); - Cryo: NR
Schmidt (2014)80 Germany | - Prospective, comparative observational; - Poor quality; - Multicenter (55 sites); - 1^st^ and 2^nd^ line therapy (% NR) | N = 3775 63% men Age = 63 years (median) [underlined: RFA:] n = 2870 62.7% men Age = 73 years (median) [underlined: Cryo:] n = 905 64.3% male Age = 63 years (median) [underlined: Special Population:] No | [underlined: Left atrial diameter:] NR [underlined: AF duration:] NR^*^ | [underlined: FU:] 100%, periprocedural [underlined: Blanking period:] NR [underlined: % crossover:] NR | [underlined: RFA Ablation:]; - PVI (100%); - 56.2% of patients received AADs at time of hospital discharge; - Class III AADs: 20.6%; - Class I AADs: 33.1%; - Class IV AADs: 3%; - Anticoagulated using phenprocoumon aiming an INR of 2 – 3 at least 3 months after procedure (dose NR) 90.5%; - Antithrombotic agents (dose NR) 11.9%; - Low molecular weight heparin (dose NR) 67.1%; [underlined: Cryoballoon Ablation:]; - PVI (100%); - 48% patients received AADs at time of hospital discharge; - Class II AADs: 21.3%; - Class I AADs: 25.1%; - Class IV AADs: 0.6%; - Anticoagulated using phenoprocoumon aiming an INR of 2 – 3 at least 3 months after procedure (dose NR) 85%; - Antithrombotic agents (dose NR) 11.9%; - Low molecular weight heparin (dose NR) 54.1%; - Touch-up: Additional touch-up freezes with a conventional cryocatheter (Freezor MAX, CryoCath, Medtronic) or an RF catheter could be performed if deemed necessary: touchup focal cryoablation was reported in 10.6% of patients; [underlined: Mapping:]; - Electroanatomic mapping system (CARTO, Biosense Webster, Diamond Bar, CA or NavX, St. Jude Medical, St. Paul, MN); Conventional mapping (28.5% of patients, device NR), 3D electroanatomical mapping (71.2% of patients)

3D = 3 dimensional; AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; CB = cryoballoon; CFAE = Complex fractionated atrial electrograms; CI = Confidence Interval; ECG = Electrocardiography; FU = Followup; IQR = Interquartile range; INR = International Normalized Ratio; NR = Not reported; PVI = Pulmonary Vein Isolation; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SD = Standard deviation.

* Percentage of patients with palpitations, palpitations monthly, and a severity and atrial fibrillation (SAF) scale are reported in supplementary tables in SRDR.

† Authors report propensity score matched subgroup analysis in those patients who received cryoballoon only (n = 51) versus RFA only (n = 51)

Table E16 Demographics of Included RCTs or Comparative Observational Studies Comparing Ablation with Different Energy Sources in Patients with Paroxysmal or Persistent Atrial Fibrillation

Author (year) | Study Design (Study Quality) | Demographics | Patient Characteristics | Followup Blanking Period % Crossover | Interventions
Herrera Siklody (2012)81 Germany, France | - RCT; - Poor quality; - Single center; - 2^nd^ line therapy | N = 60 80% male Age = 56.5 years [underlined: RFA:] n = 30 76.7% male Age = 56 ± 10 years [underlined: Cryo:] n = 30 83.3% male Age = 57 ± 8 years [underlined: Special Population:] 100% drug-resistant symptomatic AF | [underlined: Left atrial diameter:] RFA: 40.4 ± 5.5 mm Cryo: 41.4 ± 4.3 mm [underlined: AF duration:] RFA: 5.6 ± 4.2 years Cryo: 4.2 ± 2.7 years | [underlined: FU:] 12 mo (median) [underlined: Blanking period:] 3 mo [underlined: % crossover:] NR | [underlined: RFA:]; - Circumferential PVI of both ipsilateral veins %NR; - Oral anticoagulation was stopped 2 days prior to intervention; - AAD treatment suspended day of procedure, restarted the following day, and stopped after 2 months; [underlined: Cryo:]; - Balloon was inflated in front of each PV ostium and advanced to achieve PV occlusion %NR; - Each PV frozen twice over 5 minutes; - Oral anticoagulation was stopped 2 days prior to intervention; - AAD treatment suspended day of procedure, restarted the following day, and stopped after 2 months; - Electrical isolation was completed with focal applications 33% (10/30) in the cryoballoon group; [underlined: Mapping]; - RFA: Circular mapping catheter (Optima, St. Jude Medical); - Cryo: Circular mapping catheter (Optima, St. Jude Medical)
Kojodjojo (2010)82 United Kingdom | - Retrospective, comparative observational; - Poor quality; - Single center; - 2^nd^ line therapy | N = 143 76% male Age = 58 years [underlined: RFA:] n = 53 77% male Age = 59.3 ± 9.7 years [underlined: Cryo:] n = 90^*^ 75% male Age = 57.3 ± 9.4 years [underlined: Special Population:] No | [underlined: Left atrial diameter:] RFA: 41.6 ± 5.4 mm (mean) Cryo: 39.6 ± 7.1 mm (mean) [underlined: AF duration:] RFA: 6.0 ± 4.8 years Cryo: 5.6 ± 4.1 years | [underlined: FU:] RFA: % NR, 15.6 ± 7.4 mo Cryo: % NR, 14.9 ± 7.7 mo^*^ [underlined: Blanking period:] 3 mo [underlined: % crossover:] NR | [underlined: RFA:]; - Circumferential antral ablation (PVI alone) 15%; - If typical AF detected before or during procedure, cavotricuspid isthmus ablation performed 11.3% (6/53); - AADs except amiodarone stopped at least 5 half lives before treatment; - Warfarin stopped 5 days prior to procedure with briding tinzaparin (175 IU/kg) %NR; - Anticoagulation was continued for at least 3 months; [underlined: Cryo:]; - Cryoballoon ablation alone 40%; - PVI + ostial focal cryoablation 60%; - Two 5 min cryoballoon applications were applied to each PV (100%); - AADs except amiodarone stopped at least 5 half lives before treatment; - Warfarin stopped 5 days prior to procedure with briding tinzaparin (175 IU/kg) (%NR); - Anticoagulation was continued for at least 3 months; - Touch-up: PVI + cavotricuspid isthmus ablation with RFA catheter 23%; [underlined: Mapping]; - RFA: Either fluoroscopy or a three-dimensional mapping system (Carto, Biosense Webster, USA); electroanatomical mapping system 96.2% (51/53); - Cryo: Curvilenear mapping catheter (Inquiry Optima, St. Jude Medical OR Lasso, Biosense Webster, Diamond Bar, CA) % NR
Mandell (2013)83 New York | - Retrospective, comparative observational; - Poor quality; - Single center; - Both 1^st^ and 2^nd^ line therapy | N = 124 66.1% male Age = 60.7 years [underlined: RFA:] n = 62 74.2% male Age = 60.4 ± 8.4 years [underlined: Cryo:] n = 62 58.1% male Age = 61 ± 8.8 years [underlined: Special Population:] No | [underlined: Left atrial diameter:] RFA: 25.0% dilated (mode NR) Cryo: 23.4% dilated (mode NR) [underlined: AF Duration:] NR | [underlined: FU:] 100% (124/124); No followup, just periprocedural [underlined: Blanking period:] None used [underlined: % Crossover:] RFA: NR Cryo: 25.8% (16/62) patients received RF to treat right-sided isthmus dependent atrial flutter; 3.2% (2/62) patients had concomitant RF left-sided lines created | [underlined: RFA Ablation:]; - PVI only 79% (49/62); - PVI + cavotricuspid isthmus for atrial flutter 9.7% (6/62); - PVI + supraventricular tachycardia 1.6% (1/62); - PVI + superior vena cavae 3.2% (2/62); - PVI + lines 1.6% (1/62); - PVI + cavotricuspid isthmus for atrial flutter + lines 1.6% (1/62); - CFE only 1.6% (1/62); - PVI + CFE 1.6% (1/62); - Most patients who were on warfarin therapy underwent the procedure on therapeutic anticoagulation; - Patients not on therapy and in sinus rhythm were started on therapeutic anticoagulation after the procedure; [underlined: Cryoballoon Ablation:]; - PVI only 75.8% (47/62); - PVI + cavotricuspid isthmus for atrial flutter 21% (13/62); - PVI + lines 3.2% (2/62); - Most patients who were on warfarin therapy underwent the procedure on therapeutic anticoagulation; - Patients not on therapy and in sinus rhythm were started on therapeutic anticoagulation after the procedure; [underlined: Mapping:]; - Imaging was performed with intracardiac echocardiography (to assist with the transeptal punctures and monitor for pericardial effusion), single-plane fixed fluoroscopy, and nonfluoroscopic three-dimensional electroanatomical imaging (Ensite NavX; St. Jude Medical) in all patients

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; CFAE = Complex fractionated atrial electrograms; CI = Confidence Interval; ECG = Electrocardiography; FU = Followup; IQR = Interquartile range; NR = Not reported; PVI = Pulmonary Vein Isolation; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SD = Standard deviation.

* The study reports two different n’s and followups for the cryoballoon ablation group.

Table E17 Study Characteristics of Included RCTs or Comparative Observational Studies Comparing Ablation with Different Energy Sources in Patients with Paroxysmal Atrial Fibrillation

Author (year) | Study Design (Quality rating) | Inclusion Criteria | Exclusion Criteria | Outcomes | Funding
Perez-Castellano (2014)76 | - RCT (COR Trial); - Fair quality; - Single center; - 100% 2^nd^ line therapy | - Symptomatic paraoxysmal AF (>2 episodes in the last 6 months); - Refractory to 1 or more antiarrhythmic drugs (class I or III); - Anatomic pattern consisting of 4 single PVs | - Ages <18 or >75 years; - Prior AF ablation; - Prio cardiac surgery; - Moderate to severe valvular heart disease; - Anteroposterior diameter of the left atrium >50 mm (parasternal long-axis view); - Hyperthyroidism; - Intracardiac thrombus; - Contraindications for anticoagulant therapy; - Concomitant acute illness; - Pregnancy; - Unavailability for followup at center for at least 1 year | [underlined: Primary]; - NR; [underlined: Secondary]; - Freedom from recurrence; - Reablation; - Atrial flutter; - AF burden; [underlined: Adverse events]: various | - [underlined: Funding:] NR; - [underlined: COI:] NR
Chierchia (2010)77 Belgium | - Prospective nonRCT; - Poor quality; - Single center; - 100% 2^nd^ line therapy | - Frequent occurrence of recurrent episodes of AF; - Self-terminating within 7 days; - Developing in spite of treatment with at least two antiarrhythmic drugs. | - NR | [underlined: Primary]; - NR; [underlined: Secondary]; - NR; [underlined: Adverse events]: various | - [underlined: Funding]: NR; - [underlined: COI]: the authors report no conflict of interest
Knecht (2014)78 Switzerland | - Prospective comparative observational (BEAT-AF-PVI cohort study); - Fair quality; - Multicenter (2 sites); - 2^nd^ line therapy | - Paroxysmal AF undergoing PVI | - Persistent or permanent AF; - History of previous left atrial procedure (surgical or percutaneous); - Use of magnetic navigation system | [underlined: Primary]; - NR; [underlined: Secondary]; - Freedom from recurrence; [underlined: Adverse events]: NR | - [underlined: Funding:] Grants from the Basel University, the “Freiwillige Akademische Gesellschaft” (FAG) Basel, the University Hospital Basel, Bayer, Daiichi-Sankyo, and Sanofi-Aventis. Author D. Conen was supported by a grant of the Swiss National Science Foundation (PP00P3_1331681); - [underlined: COI:] Multiple authors reported conflicts of interest
Mugnai (2014)79 Belgium, Italy | - Retrospective, comparative observational; - Poor quality; - Single center; - 2^nd^ line therapy | - Documented symptomatic paroxysmal AF | - Repeat procedures for recurrent AF after index procedure; - (Previous?) first-line ablation treatment; - Acute complications disrupting procedure continuation; - Persistent AF | [underlined: Primary]; - TIA; - Death; [underlined: Secondary]; - Freedom from AF without AADs; [underlined: Adverse events]: various | - [underlined: Funding:] NR; - [underlined: COI]: Multiple authors reported conflicts of interest
Schmidt (2014)80 Germany | - Retrospective, comparative observational; - Poor quality; - Multicenter (55 sites); - 1^st^ and 2^nd^ line therapy (% NR) | - Symptomatic paroxysmal AF, defined as AF lasting <6 days with spontaneous termination; - Underwent PV ablation | - NR | [underlined: Primary]; - NR; [underlined: Secondary]; - NR; [underlined: Adverse events]: various | - [underlined: Funding:] Unrestricted grant from foundation Stiftung Institut fur Herzinfarkt-forschung Ludwigshafen, Germany; - [underlined: COI:] Multiple authors reported conflicts of interest

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; AV = atrioventricular; CFAE = Complex fractionated atrial electrograms; CI = Confidence Interval; ECG = Electrocardiography; FU = Followup; IQR = Interquartile range; MACCE = major adverse cardiac and cerebrovascular event; NR = Not reported; PVI = Pulmonary Vein Isolation; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SD = Standard deviation.

Table E18 Study Characteristics of Included RCTs or Comparative Observational Studies Comparing Ablation with Different Energy Sources in a Mixed Population

Author (year) | Study Design (Quality rating) | Inclusion Criteria | Exclusion Criteria | Outcomes | Funding
Herrera Siklody (2012)81 Germany, France | - RCT; - Poor quality; - Single center; - 2^nd^ line therapy | - Highly symptomatic, drug-refractory paroxysmal or persistent episodes of AF | - Long persistent AF (>12 months); - Left atrial diameter >55 mm; - Intracardiac thrombi determined by TEE; - MI or cardiac surgery in the previous 3 months; - Previous ablation for AF | [underlined: Primary]; - NR; [underlined: Secondary]; - Freedom from recurrence; - reablation; - atrial flutter; - biomarkers; [underlined: Adverse events]: various | - [underlined: Funding:] Study received financial support from CryoCath; - [underlined: COI:] Multiple authors report conflicts of interest
Kojodjojo (2010)82 United Kingdom | - Retrospective, comparative observational; - Poor quality; - Single center; - 2^nd^ line therapy | - Symptomatic, medically refractory AF; - Paroxysmal AF or early persistent AF; - Undergoing first AF procedure | - NR | [underlined: Primary] NR [underlined: Secondary]; - Freedom from recurrence; - Reablation; [underlined: Adverse events]: various | - [underlined: Funding:] British Heart Foundation; Dr. Kojodjojo is funded by British Heart Foundation Travel Fellowship (FS/09/047); - [underlined: COI:] The authors report no conflict of interest
Mandell (2013)83 New York | - Retrospective nonRCT; - Poor quality; - Single center; - Both 1^st^ and 2^nd^ line therapy | - Symptomatic atrial fibrillation; - Failed or couldn't tolerate antiarrhythmic drug therapy | - No RF-only ablations since the introduction of cryoballoon ablation were included. | [underlined: Primary]; - None; [underlined: Secondary]; - Freedom from protocol defined treatment failure; [underlined: Adverse events]: various | - [underlined: Funding]: NR; - [underlined: COI]: The authors report no conflict of interest

AF = Atrial Fibrillation; AAD = antiarrhythmic drugs; CFAE = Complex fractionated atrial electrograms; CI = Confidence Interval; ECG = Electrocardiography; FU = Followup; IQR = Interquartile range; NR = Not reported; PVI = Pulmonary Vein Isolation; RCT = Randomized Controlled Trial; RFA = Radiofrequency Ablation; SD = Standard deviation; TEE = Transesophogeal Echocardiography