# Sample Data Extraction Forms

Key Questions Addressed

Publications

Design:

1. Study design (RCT, prospective nonrandomized trial, retrospective nonrandomized trial)
2. Direct funding source
3. Conflict(s) of interest (CoI)
4. Country
5. Number of centers
6. Study objective
7. Inclusion Criteria
8. Exclusion criteria
9. Enrollment period (MM/YYYY – MM/YYYY)
10. Number of patients approached/considered
11. Number of patients eligible
12. Number of patients enrolled
13. Complete follow-up % (n/N)
14. Length follow-up
15. 100% of patients have the following: (Paroxysmal AF, Persistent AF, Permanent AF, Previously failed rate or rhythm control medical therapy, Medicare population, Women, Race/ethnicity, heart failure, hypertension, coronary artery disease, diabetes, kidney disease, hypertrophic cardiomyopathy, thyroid disease, pulmonary disease, obstructive sleep apnea, enlarged left atrium, other heart disease, high risk for stroke or bleeding events, stroke risk categories, history of prior stroke, obesity, atrial fibrosis, other)
16. Comments

Arms

Arm Details:

1. Number of patients enrolled
2. Number of patients treated
3. Number of patients who completed follow-up
4. Was treatment a first or second-line therapy?
5. Ablation: approach(es) (% (n/N))
6. Goal of the isolation/ablation procedure
7. Ablation successful (% (n/N))
8. Ablation: catheter tip details
9. Ablation: max energy (W)
10. Ablation: max temp (°C)
11. Ablation: total procedural time (min)
12. Ablation: total fluoroscopy time (min)
13. Ablation: mapping details
14. Was intracardiac echocardiography used?
15. Pre-procedural imaging details
16. Re-ablation
17. Ablation: other details
18. Rhythm or rate control meds: general info and duration
19. Rhythm or rate control meds: drug (dosage) (% (n/N))
20. Cardioversion performed?
21. Anticoagulant(s): drug (dosage) (usage period)
22. Blanking period used?
23. Action if AF recurred (specify length of time after initiation of initial treatment)
24. Was crossover permitted?
25. Other intervention details
26. Comments

Baselines:

1. Which population does this study describe? (general, medicare)
2. Age (mean +/− SD)
3. Male: n/N (%)
4. Race/ethnic group(s) (% (n/N))
5. Atrial fibrillation (paroxysmal AF, persistent AF, permanent AF)
6. Duration of symptoms (mean +/− SD)
7. Echocardiographic parameters
8. Comorbidities (% (n/N))

Outcomes

1. Outcome title
2. Type (continuous, categorical, other)
3. Units
4. Follow-up time points
5. Subgroups
6. Outcome description
7. Notes

Outcome Details

Results

1. Varied based on outcome

Adverse Events

2. Title
3. Description
4. n/N (%)
5. follow-up

Quality:

1. Randomization sequence (RCTs only)
2. Allocation concealment (RCTs only)
3. Intention to treat (RCTs only)
4. Blinded outcome assessment
5. Patients blinded to treatment received
6. Attrition acceptable and comparable between groups
7. Controlled for confounding (RCTs only)
8. Controlled for confounding (nonrandomized comparative studies)
9. Full reporting on prespecified outcomes
10. Quality Guideline used
11. Current overall rating
12. Notes on this rating