# List of Excluded Studies with Rationale1 –53

1 Al-Khatib SM, Allen LaPointe NM, Chatterjee R, et al. Rate- and rhythm-control therapies in patients with atrial fibrillation: a systematic review. [Review]. Ann Intern Med. Jun. 3. 2014;160(11):760-773. [pmid: 24887617]. Duplicate SR.
2 Ardagh MW, Pitchford AM, Esson A, et al. Project RED--a successful methodology for improving emergency department performance. N Z Med J. Oct. 14. 2011;124(1344):54-63. [pmid: 22016164]. Does not address Key Questions.
3 Bertaglia E, Fassini G, Anselmino M, et al. Comparison of ThermoCool Surround Flow catheter versus ThermoCool catheter in achieving persistent electrical isolation of pulmonary veins: a pilot study. Journal of Cardiovascular Electrophysiology. Mar. 2013;24(3):269-273. [pmid: 23210452]. Not a comparison of interest.
4 Bessiere F, Chevalier P. Pulmonary vein hematoma after atrial fibrillation cryoablation: a new complication. Heart Rhythm. Sep. 2013;10(9):1359. [pmid: 22561845]. Wrong study type (case-report).
5 Bohnen M, Stevenson WG, Tedrow UB, et al. Incidence and predictors of major complications from contemporary catheter ablation to treat cardiac arrhythmias. Heart Rhythm. Nov. 2011;8(11):1661-1666. [pmid: 21699857]. N < 1,000, case-series.
6 Boho A, Misikova S, Spurny P, et al. Complications of circumferential pulmonary vein isolation using the cryoballoon technique: Incidence and predictors. International Journal of Cardiology. Feb. 1. 2014;171(2):217-223. [pmid: 24387893]. Case-series, n < 1,000.
7 Bordignon S, Chun KR, Gunawardene M, et al. Comparison of balloon catheter ablation technologies for pulmonary vein isolation: the laser versus cryo study. Journal of Cardiovascular Electrophysiology. Sep. 2013;24(9):987-994. [pmid: 23800359]. Investigational device / not FDA approved.
8 Brodsky MA. Letter by Brodsky regarding article "Treatment of atrial fibrillation with antiarrhythmic drugs or radiofrequency ablation: two systematic literature reviews and meta-analyses". Circ. Dec. 2009;2(6). e44. author reply e5–6. [pmid: 20009071]. Not a comparison of interest.
9 Bunch TJ, May HT, Bair TL, et al. Atrial fibrillation ablation patients have long-term stroke rates similar to patients without atrial fibrillation regardless of CHADS2 score. Heart Rhythm. Sep. 2013;10(9):1272-1277. [pmid: 23835257]. Wrong comparison, no safety data.
10 Camm AJ, Breithardt G, Crijns H, et al. Real-life observations of clinical outcomes with rhythm- and rate-control therapies for atrial fibrillation RECORDAF (Registry on Cardiac Rhythm Disorders Assessing the Control of Atrial Fibrillation). Journal of the American College of Cardiology. Jul. 26. 2011;58(5):493-501. [pmid: 21777747]. Not an intervention of interest.
11 Chambers D, Rodgers M, Woolacott N. Not only randomized controlled trials, but also case series should be considered in systematic reviews of rapidly developing technologies. J Clin Epidemiol. Dec. 2009;62(12):1253-1260.e4. [pmid: 19349144]. Not a comparison of interest.
12 Chang CH, Lin JW, Chiu FC, et al. Effect of radiofrequency catheter ablation for atrial fibrillation on morbidity and mortality: a nationwide cohort study and propensity score analysis. Circ. Feb. 2014;7(1):76-82. Wrong comparison, no safety data.
13 Da Costa A, Thevenin J, Roche F, et al. Results from the Loire-Ardeche-Drome-Isere-Puy-de-Dome (LADIP) Trial on Atrial Flutter, a multicentric prospective randomized study comparing amiodarone and radiofrequency ablation after the first episode of symptomatic atrial flutter. Circulation. 2006;114(16):1676-1681. [pmid: 17030680]. Not a population of interest.
14 De Ponti R, Lumia D, Marazzi R, et al. Left atrial diverticula in patients undergoing atrial fibrillation ablation: morphologic analysis and clinical impact. Journal of Cardiovascular Electrophysiology. Nov. 2013;24(11):1232-1239. [pmid: 23875875]. Case-series, n < 1,000.
15 Fasol R, Meinhart J, Binder T. A modified and simplified radiofrequency ablation in patients with mitral valve disease. J Thorac Cardiovasc Surg. Jan. 2005;129(1):215-217. [pmid: 15632848]. No outcomes of interest.
16 Gaita F, Leclercq JF, Schumacher B, et al. Incidence of silent cerebral thromboembolic lesions after atrial fibrillation ablation may change according to technology used: comparison of irrigated radiofrequency, multipolar nonirrigated catheter and cryoballoon. Journal of Cardiovascular Electrophysiology. Sep. 2011;22(9):961-968. [pmid: 21453372]. Not an outcome of interest.
17 Giovannib F, Massimo M, Lucia De L, et al. Catheter ablation of atrial fibrillation in patients with diabetes mellitus type 2: results from a randomized study comparing pulmonary vein isolation versus antiarrhythmic drug therapy. Journal of Cardiovascular Electrophysiology. 2009;20(1):22-28. CN-00866400 NEW. [pmid: 18775050]. Same population as a prior included study (Packer, 2013).
18 Haeusler KG, Koch L, Herm J, et al. 3 Tesla MRI-detected brain lesions after pulmonary vein isolation for atrial fibrillation: results of the MACPAF study. Journal of Cardiovascular Electrophysiology. Jan. 2013;24(1):14-21. [pmid: 22913568]. Investigational device / not FDA approved.
19 Hanley CM, Esberg D, Kowey PR. Ablation versus drugs: what is the best first-line therapy for paroxysmal atrial fibrillation? Antiarrhythmic drugs are outmoded and catheter ablation should be the first-line option for all patients with paroxysmal atrial fibrillation: con. Circ. Aug. 2014;7(4):747-754. Wrong study type (comment/editorial/review).
20 Herm J, Fiebach JB, Koch L, et al. Neuropsychological effects of MRI-detected brain lesions after left atrial catheter ablation for atrial fibrillation: long-term results of the MACPAF study. Circ. Oct. 2013;6(5):843-850. [pmid: 23989301]. Investigational device / not FDA approved.
21 Hindricks G, Packer DL. Moving catheter ablation forward from paroxysmal to persistent atrial fibrillation: progress, limitations, and surprises of the SARA trial. European heart journal. Feb. 2014;35(8):482-484. [pmid: 24371081]. Wrong study type (comment/editorial/review).
22 Hussein AA, Wazni OM, Harb S, et al. Radiofrequency ablation of atrial fibrillation in patients with mechanical mitral valve prostheses safety, feasibility, electrophysiologic findings, and outcomes. Journal of the American College of Cardiology. Aug. 2. 2011;58(6):596-602. [pmid: 21798422]. N < 100 patients.
23 Jones DG, Wong T. Catheter ablation versus rate control for atrial fibrillation: what have we learnt from the ARC-HF trial? [Review]. Future Cardiology. Sep. 2013;9(5):599-602. [pmid: 24020656]. Wrong study type (comment/editorial/review).
24 Kaba RA, Cannie D, Ahmed O. RAAFT-2: Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of paroxysmal atrial fibrillation. Global Cardiology Science and Practice. 2014;2. CN-01002382 NEW. Wrong study type (review of included study, Morillo).
25 Khaykin Y, Skanes A, Champagne J, et al. A randomized controlled trial of the efficacy and safety of electroanatomic circumferential pulmonary vein ablation supplemented by ablation of complex fractionated atrial electrograms versus potential-guided pulmonary vein antrum isolation guided by intracardiac ultrasound. Circ. Oct. 2009;2(5):481-487. [pmid: 19843915]. Not a comparison of interest.
26 Khaykin Y, Wang X, Natale A, et al. Cost comparison of ablation versus antiarrhythmic drugs as first-line therapy for atrial fibrillation: an economic evaluation of the RAAFT pilot study. Journal of Cardiovascular Electrophysiology. Jan. 2009;20(1):7-12. [pmid: 18803564]. Not a study type of interest.
27 Khurram IM, Dewire J, Mager M, et al. Relationship between left atrial appendage morphology and stroke in patients with atrial fibrillation. Heart Rhythm. Dec. 2013;10(12):1843-1849. [pmid: 24076444]. Case-series, n < 1,000.
28 Kim JB, Cho W-C, Jung SH, et al. Alternative energy sources for surgical treatment of atrial fibrillation in patients undergoing mitral valve surgery: microwave ablation vs cryoablation. J Korean Med Sci. Oct. 2010;25(10):1467-1472. [pmid: 20890428]. Not a comparison of interest.
29 Koch L, Haeusler KG, Herm J, et al. Mesh ablator vs. cryoballoon pulmonary vein ablation of symptomatic paroxysmal atrial fibrillation: results of the MACPAF study. Europace. Oct. 2012;14(10):1441-1449. [pmid: 22523379]. Investigational device / not FDA approved.
30 Kosiuk J, Nedios S, Kornej J, et al. Impact of left atrial appendage morphology on peri-interventional thromboembolic risk during catheter ablation of atrial fibrillation. Heart Rhythm. 2014;11(9):1522-1527. CN-01002159 NEW. [pmid: 24858813]. Case-series, n < 1,000.
31 Kuhne M, Schaer B, Ammann P, et al. Cryoballoon ablation for pulmonary vein isolation in patients with paroxysmal atrial fibrillation. Swiss Med Wkly. Apr. 17. 2010;140(15–16):214-221. [pmid: 20407957]. N < 100 patients, observational study.
32 Li X, Wissner E, Kamioka M, et al. Safety and feasibility of transseptal puncture for atrial fibrillation ablation in patients with atrial septal defect closure devices. Heart Rhythm. Feb. 2014;11(2):330-335. [pmid: 24239844]. Case-series, n < 1,000.
33 Lin YJ, Tai CT, Chang SL, et al. Efficacy of additional ablation of complex fractionated atrial electrograms for catheter ablation of nonparoxysmal atrial fibrillation. Journal of Cardiovascular Electrophysiology. Jun. 2009;20(6):607-615. CN-00723024 UPDATE. [pmid: 19642225]. N < 100 patients, observational study.
34 Lin Z, Shan ZG, Liao CX, et al. The effect of microwave and bipolar radio-frequency ablation in the surgical treatment of permanent atrial fibrillation during valve surgery. Thorac Cardiovasc Surg. Dec. 2011;59(8):460-464. [pmid: 21692021]. Not a comparison of interest.
35 Linhart M, Bellmann B, Mittmann-Braun E, et al. Comparison of cryoballoon and radiofrequency ablation of pulmonary veins in 40 patients with paroxysmal atrial fibrillation: a case-control study. Journal of Cardiovascular Electrophysiology. Dec. 2009;20(12):1343-1348. [pmid: 19656254]. N < 100 patients, observational study.
36 Liu Z, Ling Z, Su L, et al. The effect of different treatment strategies on left atrial size in patients with lone paroxysmal atrial fibrillation-a prospective cohort study. Journal of Interventional Cardiac Electrophysiology. Dec. 2008;23(3):167-173. [pmid: 18810622]. Same population as prior included study (Lan, 2009).
37 Magnani JW, Benjamin EJ. Where do we come from? Where are we going? Adverse outcomes in catheter ablation for atrial fibrillation. Circ. Apr. 2014;7(2):195-197. Wrong study type (comment/editorial/review).
38 Malmborg H, Lonnerholm S, Blomstrom P, et al. Ablation of atrial fibrillation with cryoballoon or duty-cycled radiofrequency pulmonary vein ablation catheter: a randomized controlled study comparing the clinical outcome and safety; the AF-COR study. Europace. Nov. 2013;15(11):1567-1573. Wrong intervention (phased RFA). [pmid: 23703361]. Investigational device/ not FDA approved.
39 Marrouche NF, Guenther J, Segerson NM, et al. Randomized comparison between open irrigation technology and intracardiac-echo-guided energy delivery for pulmonary vein antrum isolation: procedural parameters, outcomes, and the effect on esophageal injury. Journal of Cardiovascular Electrophysiology. Jun. 2007;18(6):583-588. [pmid: 17490437]. Not a study type of interest.
40 Martin F, Jan C, Renata N, et al. Pulmonary vein isolation using segmental versus electroanatomical circumferential ablation for paroxysmal atrial fibrillation: over 3-year results of a prospective randomized study. Journal of Interventional Cardiac Electrophysiology. 2008;22(1):13-21. CN-00873182 NEW. [pmid: 18418704]. Not a study type of interest.
41 Metzner A, Wissner E, Schoonderwoerd B, et al. The influence of varying energy settings on efficacy and safety of endoscopic pulmonary vein isolation. Heart Rhythm. Sep. 2012;9(9):1380-1385. [pmid: 22472520]. Not a study type of interest.
42 Neumann T, Kuniss M, Conradi G, et al. MEDAFI-Trial (Micro-embolization during ablation of atrial fibrillation): comparison of pulmonary vein isolation using cryoballoon technique vs. radiofrequency energy. Europace. Jan. 2011;13(1):37-44. [pmid: 20829189]. N < 100 patients, observational study.
43 Phan K, Xie A, La Meir M, et al. Surgical ablation for treatment of atrial fibrillation in cardiac surgery: a cumulative meta-analysis of randomised controlled trials [Review]. Heart. May. 2014;100(9):722-730. [pmid: 24650881]. Wrong intervention (surgical ablation), SR.
44 Piccini JP, Stevens SR, Lokhnygina Y, et al. Outcomes after cardioversion and atrial fibrillation ablation in patients treated with rivaroxaban and warfarin in the ROCKET AF trial. Journal of the American College of Cardiology. May. 2013;61(19):1998-2006. CN-00877029 NEW. [pmid: 23500298]. No outcomes of interest.
45 Richter B, Gwechenberger M, Socas A, et al. Frequency of recurrence of atrial fibrillation within 48 hours after ablation and its impact on long-term outcome. American Journal of Cardiology. Mar. 15. 2008;101(6):843-847. [pmid: 18328850]. Not an intervention of interest.
46 Roberts A. Atrial fibrillation: Catheter ablation as a first-line AF therapy: the RAAFT-2 trial. Nature Reviews Cardiology. Apr. 2014;11(4):188. Wrong study type (comment/editorial/review).
47 Sauren LD, Van Belle Y, De Roy L, et al. Transcranial measurement of cerebral microembolic signals during endocardial pulmonary vein isolation: comparison of three different ablation techniques. Journal of Cardiovascular Electrophysiology. Oct. 2009;20(10):1102-1107. [pmid: 19549035]. N < 100 patients, observational study.
48 Schmidt B, Gunawardene M, Krieg D, et al. A prospective randomized single-center study on the risk of asymptomatic cerebral lesions comparing irrigated radiofrequency current ablation with the cryoballoon and the laser balloon. Journal of Cardiovascular Electrophysiology. Aug. 2013;24(8):869-874. [pmid: 23601001]. No outcomes of interest.
49 Tse HF, Kwong YL, Lau CP. Transvenous cryoablation reduces platelet activation during pulmonary vein ablation compared with radiofrequency energy in patients with atrial fibrillation. Journal of Cardiovascular Electrophysiology. Oct. 2005;16(10):1064-1070. CN-00530690 UPDATE. [pmid: 16191116]. Not an intervention of interest.
50 US Food and Drug Administration (FDA). Summary of Safety and Effectiveness Data (SSED): Arctic Front Cardiac CryoAblation Catheter System, accessed 10/24/12 at http://www.accessdata.fda.gov/cdrh_docs/pdf10/P100010b.pdf. 2010. Same population as prior included study (Packer, 2013).
51 Wissner E, Metzner A, Neuzil P, et al. Asymptomatic brain lesions following laserballoon-based pulmonary vein isolation. Europace. Feb. 2014;16(2):214-219. [pmid: 23933850]. Investigational device/ not FDA approved.
52 Won H, Kim JY, Shim J, et al. Effect of a single bolus injection of low-dose hydrocortisone for prevention of atrial fibrillation recurrence after radiofrequency catheter ablation. Circulation Journal. 2013;77(1):53-59. CN-00917553 NEW. [pmid: 23006726]. N < 100 patients, observational study.
53 Xu J, Huang Y, Cai H, et al. Is cryoballoon ablation preferable to radiofrequency ablation for treatment of atrial fibrillation by pulmonary vein isolation? A meta-analysis. PLoS ONE [Electronic Resource]. 2014;9(2):e90323. SR, references checked.