# List of Included Studies

1 Andrade JG, Khairy P, Macle L, et al. Incidence and significance of early recurrences of atrial fibrillation after cryoballoon ablation: insights from the multicenter Sustained Treatment of Paroxysmal Atrial Fibrillation (STOP AF) Trial. Circ Arrhythm Electrophysiol. Feb. 2014;7(1):69-75. [pmid: 24446022].
2 Baman TS, Jongnarangsin K, Chugh A, et al. Prevalence and predictors of complications of radiofrequency catheter ablation for atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2011;22(6):626-631. [pmid: 21235674].
3 Bertaglia E, Zoppo F, Tondo C, et al. Early complications of pulmonary vein catheter ablation for atrial fibrillation: a multicenter prospective registry on procedural safety. Heart Rhythm. Oct. 2007;4(10):1265-1271. [pmid: 17905330].
4 Blandino A, Toso E, Scaglione M, et al. Long-term efficacy and safety of two different rhythm control strategies in elderly patients with symptomatic persistent atrial fibrillation. Journal of Cardiovascular Electrophysiology. Jul. 2013;24(7):731-738. [pmid: 23551460].
5 Bunch TJ, Crandall BG, Weiss JP, et al. Patients treated with catheter ablation for atrial fibrillation have long-term rates of death, stroke, and dementia similar to patients without atrial fibrillation. Journal of Cardiovascular Electrophysiology. Aug. 2011;22(8):839-845. [pmid: 21410581].
6 Chierchia GB, Capulzini L, Droogmans S, et al. Pericardial effusion in atrial fibrillation ablation: a comparison between cryoballoon and radiofrequency pulmonary vein isolation. Europace. Mar. 2010;12(3):337-341. [pmid: 20056597].
7 Cosedis Nielsen J, Johannessen A, Raatikainen P, et al. Radiofrequency ablation as initial therapy in paroxysmal atrial fibrillation. N Engl J Med. Oct. 25. 2012;367(17):1587-1595. [pmid: 23094720].
8 Dagres N, Hindricks G, Kottkamp H, et al. Complications of atrial fibrillation ablation in a high-volume center in 1,000 procedures: still cause for concern?. Journal of Cardiovascular Electrophysiology. Sep. 2009;20(9):1014-1019. [pmid: 19490383].
9 D'Ascenzo F, Corleto A, Biondi-Zoccai G, et al. Which are the most reliable predictors of recurrence of atrial fibrillation after transcatheter ablation?: a meta-analysis. International Journal of Cardiology. Sep. 1. 2013;167(5):1984-1989. [pmid: 22626840].
10 Deshmukh A, Patel NJ, Pant S, et al. In-hospital complications associated with catheter ablation of atrial fibrillation in the United States between 2000 and 2010: analysis of 93 801 procedures. Circulation. 2013;128(19):2104-2112. [pmid: 24061087].
11 Forleo GB, Mantica M, De Luca L, et al. Catheter ablation of atrial fibrillation in patients with diabetes mellitus type 2: results from a randomized study comparing pulmonary vein isolation versus antiarrhythmic drug therapy. Journal of Cardiovascular Electrophysiology. Jan. 2009;20(1):22-28. [pmid: 18775050].
12 Gibson DN, Di Biase L, Mohanty P, et al. Stiff left atrial syndrome after catheter ablation for atrial fibrillation: clinical characterization, prevalence, and predictors.[Erratum appears in Heart Rhythm. 2011 Nov;8(11):1828]. Heart Rhythm. Sep. 2011;8(9):1364-1371. [pmid: 21354332].
13 Hao SC, Hunter TD, Gunnarsson C, et al. Acute safety outcomes in younger and older patients with atrial fibrillation treated with catheter ablation. J Interv Card Electrophysiol. Nov. 2012;35(2):173-182. [pmid: 22714547].
14 Herrera Siklody C, Deneke T, Hocini M, et al. Incidence of asymptomatic intracranial embolic events after pulmonary vein isolation: comparison of different atrial fibrillation ablation technologies in a multicenter study. Journal of the American College of Cardiology. Aug. 9. 2011;58(7):681-688. [pmid: 21664090].
15 Hoyt H, Bhonsale A, Chilukuri K, et al. Complications arising from catheter ablation of atrial fibrillation: temporal trends and predictors. Heart Rhythm. Dec. 2011;8(12):1869-1874. [pmid: 21798230].
16 Hunter RJ, Berriman TJ, Diab I, et al. A randomized controlled trial of catheter ablation versus medical treatment of atrial fibrillation in heart failure (the CAMTAF trial). Circ Arrhythm Electrophysiol. Feb. 2014;7(1):31-38. [pmid: 24382410].
17 Hunter RJ, McCready J, Diab I, et al. Maintenance of sinus rhythm with an ablation strategy in patients with atrial fibrillation is associated with a lower risk of stroke and death. Heart. Jan. 2012;98(1):48-53. [pmid: 21930724].
18 Jais P, Cauchemez B, Macle L, et al. Catheter ablation versus antiarrhythmic drugs for atrial fibrillation: the A4 study.[Erratum appears in Circulation. 2009 Sep 8;120(10):e83]. Circulation. Dec. 9. 2008;118(24):2498-2505. [pmid: 19029470].
19 Jones DG, Haldar SK, Hussain W, et al. A randomized trial to assess catheter ablation versus rate control in the management of persistent atrial fibrillation in heart failure. Journal of the American College of Cardiology. 2013;61(18):1894-1903. CN-00907192 NEW. [pmid: 23500267].
20 Knecht S, Sticherling C, von Felten S, et al. Long-term comparison of cryoballoon and radiofrequency ablation of paroxysmal atrial fibrillation: a propensity score matched analysis. Int J Cardiol. Oct. 20. 2014;176(3):645-650. [pmid: 25149399].
21 Kojodjojo P, O'Neill MD, Lim PB, et al. Pulmonary venous isolation by antral ablation with a large cryoballoon for treatment of paroxysmal and persistent atrial fibrillation: medium-term outcomes and non-randomised comparison with pulmonary venous isolation by radiofrequency ablation. Heart. Sep. 2010;96(17):1379-1384. [pmid: 20801856].
22 Kosiuk J, Kornej J, Bollmann A, et al. Early cerebral thromboembolic complications after radiofrequency catheter ablation of atrial fibrillation: Incidence, characteristics, and risk factors. Heart Rhythm. Nov. 2014;11(11):1934-1940. [pmid: 25086257].
23 Lan X, Su L, Ling Z, et al. Catheter ablation vs. amiodarone plus losartan for prevention of atrial fibrillation recurrence in patients with paroxysmal atrial fibrillation. Eur J Clin Invest. Aug. 2009;39(8):657-663. [pmid: 19490069].
24 MacDonald MR, Connelly DT, Hawkins NM, et al. Radiofrequency ablation for persistent atrial fibrillation in patients with advanced heart failure and severe left ventricular systolic dysfunction: a randomised controlled trial. Heart. May. 2011;97(9):740-747. [pmid: 21051458].
25 Mandell J, Amico F, Parekh S, et al. Early experience with the cryoablation balloon procedure for the treatment of atrial fibrillation by an experienced radiofrequency catheter ablation center. J Invasive Cardiol. Jun. 2013;25(6):288-292. [pmid: 23735354].
26 Michowitz Y, Rahkovich M, Oral H, et al. Effects of sex on the incidence of cardiac tamponade after catheter ablation of atrial fibrillation: results from a worldwide survey in 34 943 atrial fibrillation ablation procedures. Circ Arrhythm Electrophysiol. Apr. 2014;7(2):274-280. [pmid: 24519888].
27 Mont L, Bisbal F, Hernandez-Madrid A, et al. Catheter ablation vs. antiarrhythmic drug treatment of persistent atrial fibrillation: a multicentre, randomized, controlled trial (SARA study). European heart journal. 2013. Oct. 17. [pmid: 24135832].
28 Morillo CA, Verma A, Connolly SJ, et al. Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of paroxysmal atrial fibrillation (RAAFT-2): a randomized trial. JAMA. Feb. 19. 2014;311(7):692-700. [pmid: 24549549].
29 Mugnai G, Chierchia GB, de Asmundis C, et al. Comparison of pulmonary vein isolation using cryoballoon versus conventional radiofrequency for paroxysmal atrial fibrillation. The American journal of cardiology. May. 1. 2014;113(9):1509-1513. [pmid: 24630388].
30 Oral H, Pappone C, Chugh A, et al. Circumferential pulmonary-vein ablation for chronic atrial fibrillation. N Engl J Med. Mar. 2. 2006;354(9):934-941. [pmid: 16510747].
31 Packer DL, Irwin JM, Champagne J. Cryoballoon ablation of pulmonary veins for paroxysmal atrial fibrillation: first results of the North American Arctic Front STOP-AF pivotal trial. J Am Coll Cardiol. 2010;55:E3015-E3016.
32 Pappone C, Augello G, Sala S, et al. A randomized trial of circumferential pulmonary vein ablation versus antiarrhythmic drug therapy in paroxysmal atrial fibrillation: the APAF Study. Journal of the American College of Cardiology. Dec. 5. 2006;48(11):2340-2347. [pmid: 17161267].
33 Pappone C, Vicedomini G, Augello G, et al. Radiofrequency catheter ablation and antiarrhythmic drug therapy: a prospective, randomized, 4-year follow-up trial: the APAF study. Circ. Dec. 2011;4(6):808-814. [pmid: 21946315].
34 Perez-Castellano N, Fernandez-Cavazos R, Moreno J, et al. The COR trial: a randomized study with continuous rhythm monitoring to compare the efficacy of cryoenergy and radiofrequency for pulmonary vein isolation. Heart Rhythm. Jan. 2014;11(1):8-14. [pmid: 24103221].
35 Piccini JP, Sinner MF, Greiner MA, et al. Outcomes of Medicare beneficiaries undergoing catheter ablation for atrial fibrillation. Circulation. Oct. 30. 2012;126(18):2200-2207. [pmid: 23019293].
36 Reynolds MR, Gunnarsson CL, Hunter TD, et al. Health outcomes with catheter ablation or antiarrhythmic drug therapy in atrial fibrillation: results of a propensity-matched analysis. Circ Cardiovasc Qual Outcomes. Mar. 1. 2012;5(2):171-181. [pmid: 22373904].
37 Reynolds MR, Walczak J, White SA, et al. Improvements in symptoms and quality of life in patients with paroxysmal atrial fibrillation treated with radiofrequency catheter ablation versus antiarrhythmic drugs. Circ Cardiovasc Qual Outcomes. Nov. 2010;3(6):615-623. [pmid: 20940250].
38 Rossillo A, Bonso A, Themistoclakis S, et al. Role of anticoagulation therapy after pulmonary vein antrum isolation for atrial fibrillation treatment. J Cardiovasc Med (Hagerstown). Jan. 2008;9(1):51-55. [pmid: 18268419].
39 Sacher F, Monahan KH, Thomas SP, et al. Phrenic nerve injury after atrial fibrillation catheter ablation: characterization and outcome in a multicenter study. J Am Coll Cardiol. Jun. 20. 2006;47(12):2498-2503. [pmid: 16781380].
40 Sang C-H, Chen K, Pang X-F, et al. Depression, anxiety, and quality of life after catheter ablation in patients with paroxysmal atrial fibrillation. Clin Cardiol. Jan. 2013;36(1):40-45. [pmid: 22777577].
41 Schmidt M, Dorwarth U, Andresen D, et al. Cryoballoon versus RF ablation in paroxysmal atrial fibrillation: results from the German Ablation Registry. J Cardiovasc Electrophysiol. Jan. 2014;25(1):1-7. [pmid: 24134539].
42 Shah RU, Freeman JV, Shilane D, et al. Procedural complications, rehospitalizations, and repeat procedures after catheter ablation for atrial fibrillation. J Am Coll Cardiol. Jan. 10. 2012;59(2):143-149. [pmid: 22222078].
43 Sonne K, Patel D, Mohanty P, et al. Pulmonary vein antrum isolation, atrioventricular junction ablation, and antiarrhythmic drugs combined with direct current cardioversion: survival rates at 7 years follow-up. J Interv Card Electrophysiol. Nov. 2009;26(2):121-126. [pmid: 19789970].
44 Srivatsa UN, Danielsen B, Anderson I, et al. Risk predictors of stroke and mortality after ablation for atrial fibrillation: The California experience 2005–2009. Heart Rhythm. Nov. 2014;11(11):1898-1903. [pmid: 25048442].
45 Stabile G, Bertaglia E, Senatore G, et al. Catheter ablation treatment in patients with drug-refractory atrial fibrillation: a prospective, multi-centre, randomized, controlled study (Catheter Ablation For The Cure Of Atrial Fibrillation Study). European heart journal. Jan. 2006;27(2):216-221. [pmid: 16214831].
46 Wazni OM, Marrouche NF, Martin DO, et al. Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of symptomatic atrial fibrillation: a randomized trial. JAMA. Jun. 1. 2005;293(21):2634-2640. [pmid: 15928285].
47 Wilber DJ, Pappone C, Neuzil P, et al. Comparison of antiarrhythmic drug therapy and radiofrequency catheter ablation in patients with paroxysmal atrial fibrillation: a randomized controlled trial. JAMA. Jan. 27. 2010;303(4):333-340. [pmid: 20103757].
48 Wynn GJ, Das M, Bonnett LJ, et al. Quality-of-life benefits of catheter ablation of persistent atrial fibrillation: a reanalysis of data from the SARA study. Europace. 2014. Jul. 15. [pmid: 25028177].
49 Yu S, Zhao Q, Wu P, et al. Effect of anxiety and depression on the recurrence of paroxysmal atrial fibrillation after circumferential pulmonary vein ablation. Journal of Cardiovascular Electrophysiology. Nov. Suppl 1. 2012;23:S17-S23. [pmid: 22998234].
50 Zado E, Callans DJ, Riley M, et al. Long-term clinical efficacy and risk of catheter ablation for atrial fibrillation in the elderly. J Cardiovasc Electrophysiol. Jun. 2008;19(6):621-626. [pmid: 18462325].