# Search Strategy

Database: Ovid MEDLINE(R) without Revisions <1996 to March Week 4 2014>

1 | Atrial Fibrillation/ or atrial fibrillation.mp. or afib.mp.
2 | 1 not (child$ or pediatri$ or infant$ or adolescent$).mp.
3 | catheter ablation.mp. or Catheter Ablation/
4 | exp Pulsed Radiofrequency Treatment/
5 | radiofrequency.mp.
6 | cryoablation.mp. or Cryosurgery/
7 | cryoballoon.mp. or Balloon Occlusion/
8 | ("pulmonary vein isolation" or "pvi").mp.
9 | or/3–8
10 | 2 and 9
11 | ("clinical trial" or "comparative study" or "controlled clinical trial" or "randomized controlled trial").pt.
12 | (random$ or control$ or trial$ or cohort or prospective or retrospective).mp.
13 | (ae or co or mo).fs.
14 | ("adverse event$" or "adverse effect$" or safety or harm$).mp.
15 | 11 or 12
16 | 13 or 14
17 | 10 and (15 or 16)
18 | limit 17 to yr="2005 -Current"
19 | limit 18 to humans
20 | limit 19 to english language

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <January 2014>

Search Strategy:

1 | Atrial Fibrillation/ or atrial fibrillation.mp. or afib.mp.
2 | 1 not (child$ or pediatri$ or infant$ or adolescent$).mp.
3 | catheter ablation.mp. or Catheter Ablation/
4 | exp Pulsed Radiofrequency Treatment/
5 | radiofrequency.mp.
6 | cryoablation.mp. or Cryosurgery/
7 | cryoballoon.mp. or Balloon Occlusion/
8 | ("pulmonary vein isolation" or "pvi").mp.
9 | or/3–8
10 | 2 and 9
11 | limit 10 to yr="2005 -Current"

Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to February 2014>

1 | Atrial Fibrillation/ or atrial fibrillation.mp. or afib.mp.
2 | 1 not (child$ or pediatri$ or infant$ or adolescent$).mp.
3 | catheter ablation.mp. or Catheter Ablation/
4 | radiofrequency.mp.
5 | cryoablation.mp. or Cryosurgery/
6 | ("pulmonary vein isolation" or "pvi").mp.
7 | or/3–6
8 | 2 and 7