# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Alexandru Costea, M.D.
  Associate Professor of Clinical Medicine
  Cardiac Electrophysiology
  University of Cincinnati
  Cincinnati, OH
- Michael Field, M.D., F.A.C.C., F.H.R.S.
  Director of Clinical Electrophysiology and Cardiac Arrhythmia Service
  University of Wisconsin
  Madison, WI
- James Reiffel, M.D., F.A.C.C., F.A.H.A., F.H.R.S.
  Faculty Physician, Electrophysiology Service
  Co-Director, Electrocardiology Laboratory
  Columbia University Medical Center
  New York, NY
- Kristen Patton, M.D.
  Division of Cardiology
  University of Washington
  Seattle, WA
- Jordan M. Prutkin, M.D., M.H.S.
  Division of Cardiology
  University of Washington
  Seattle, WA