# Technical Expert Panel

In place of a Technical Expert Panel, the Centers for Medicare and Medicaid provided input on the Key Questions and scope of the report.