# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows. Those who also reviewed the draft report are marked with an asterisk.

- *Robin Boineau, M.D., M.A.
  Medical Officer, Division of Cardiovascular Diseases
  National Heart, Lung, and Blood Institute
  National Institute of Health
  Bethesda, MD
- *Michael LeFevre, M.D., M.S.P.H., A.A.F.P.
  Future of Family Medicine Professor
  Vice Chair, Department of Family and Community Medicine
  University of Missouri School of Medicine
  Columbia, MO
- Douglas Packer, M.D., F.A.C.C., F.H.R.S.
  Department of Cardiovascular Diseases
  Mayo Clinic
  Rochester, MN
- *Hugh Calkins, M.D., F.A.C.C, F.H.R.S., F.A.H.A, C.C.D.S.
  Director, Cardiac Arrhythmia Service and Electrophysiology Lab
  Johns Hopkins University
  Baltimore, MD
- Michael Rich, M.D., A.G.S.F., F.A.C.C.
  Director, Cardiac Rapid Evaluation Unit
  Washington University
  St. Louis, MO
- *Mellanie True Hills
  Patient Advocate
  Founder and CEO, StopAfib.org
- Paul Varosy, M.D., F.A.C.C., F.A.H.A., F.H.R.S.
  Director, Electrophysiology
  Denver Veterans Administration Medical Center
  Denver, CO