# Investigator Affiliations

- Andrea Skelly, Ph.D., M.P.H.
  Spectrum Research, Inc.
  Tacoma, WA
- Robin Hashimoto, Ph.D.
  Spectrum Research, Inc.
  Tacoma, WA
- Sana Al-Khatib, M.D., M.H.S.
  Duke University
  Durham, NC
- Gillian Sanders-Schmidler, Ph.D.
  Duke University
  Durham, NC
- Rochelle Fu, Ph.D.
  Oregon Health & Sciences University
  Portland, OR
- Erika Brodt, B.S.
  Spectrum Research, Inc.
  Tacoma, WA
- Marian McDonagh, Pharm.D.
  Oregon Health & Sciences University
  Portland, OR